# References

1 Wortley PM, Fleming PL. AIDS in women in the United States. JAMA. 1997;278(11):911-916. [pmid: 9302243].
2 Lee LM, Fleming PL. Trends in human immunodeficiency virus diagnoses among women in the United States, 1994-1998. J Am Med Womens Assoc. 2001;56(3):94-99. [pmid: 11506153].
3 Recommendations for antiretroviral therapy during pregnancy: prevention for the child; treatment for the mother. Prescrire Int. 1999;8(39):24–28.
4 Davis SF, Rosen DH, Steinberg S, et al. Trends in HIV prevalence among childbearing women in the United States, 1989-1994. J Acquir Immune Defic Syndr Hum Retrovirol. 1998;19(2):158-164. [pmid: 9768625].
5 Lindegren ML, Byers RH, Thomas P, et al. Trends in perinatal transmission of HIV/AIDS in the United States. JAMA. 1999;282(6):531-538. [pmid: 10450714].
6 Centers for Disease Control and Prevention. Rapid HIV antibody testing during labor and delivery for women of unknown HIV status. Available at: http://www.cdc.gov/hiv/rapid_testing/materials/Labor&DeliveryRapidTesting.pdf. Accessed July 20, 2004.
7 Pulver W, Glebatis D, Wade N, et al. Trends from an HIV seroprevalence study among childbearing women in New York State from 1988 through 2000: a valuable epidemiologic tool. Arch Pediatr Adolesc Med. 2004;158(5):443-448. [pmid: 15123476].
8 Centers for Disease Control and Prevention. HIV/AIDS Surveillance Report. US Department of Health and Human Services, Centers for Disease Control and Prevention. Available at: http://www.cdc.gov/hiv/stats/2003SurveillanceReport.pdf. Accessed March 22, 2005.
9 Centers for Disease Control and Prevention. HIV and AIDS—United States, 1981-2000. Morb Mortal Wkly Rep. 2001;50(21):430-434.
10 Centers for Disease Control and Prevention. AIDS cases, deaths, and persons living with AIDS by year, 1985-2002—United States. Available at: http://www.cdc.gov/hiv/stats/hasr1402.htm. Accessed Dec. 2, 2004.
11 Bulterys M, Nolan ML, Jamieson DJ, et al. Advances in the prevention of mother-to-child HIV-1 transmission: current issues, future challenges. AIDScience. Available at: http://www.aidscience.org/Articles/aidscience017.asp. Accessed March 22, 2005.
12 Department of Health and Human Services. Reducing obstetrician barriers to offering HIV testing. Available at: http://www.cdc.gov/hiv/projects/perinatal/materials/ps_oig.pdf. Accessed March 22, 2005.
13 Mofenson LM. Advances in the prevention of vertical transmission of human immunodeficiency virus. Semin Pediatr Infect Dis. 2003;14(4):295-308. [pmid: 14724794].
14 Department of Health and Human Services. Public Health Service Task Force recommendations for use of antiretroviral drugs in pregnant HIV-1-infected women for maternal health and interventions to reduce perinatal HIV-1 transmission in the United States. Available at: http://aidsinfo.nih.gov/guidelines/perinatal/PER_022405.pdf. Accessed March 22, 2005.
15 Centers for Disease Control and Prevention. Guidelines for preventing opportunistic infections among HIV-infected persons—2002 recommendations of the U.S. Public Health Service and the Infectious Diseases Society of America. Morb Mortal Wkly Rep. 2002;51(RR-8):1-52.
16 Centers for Disease Control and Prevention. Recommended adult immunization schedule by age group and medical conditions United States, 2003-2004. Available at: http://www.cdc.gov/nip/recs/adult-schedule.pdf. Accessed June 28, 2004.
17 Centers for Disease Control and Prevention. Revised guidelines for HIV counseling, testing, and referral. Morb Mortal Wkly Rep. 2001;50(RR-19):1-57.
18 Centers for Disease Control and Prevention. Revised recommendations for HIV screening of pregnant women. Morb Mortal Wkly Rep—Recommendations and Reports. 2001;50(RR-19):63-85.
19 Committee on Obstetric Practice, American College of Obstetricians and Gynecologists ACOG committee opinion. Scheduled cesarean delivery and the prevention of vertical transmission of HIV infection. No. 219. Int J Gynaecol Obstet. 1999;66(3):305-306. [pmid: 10580685].
20 Centers for Disease Control and Prevention. U.S. Public Health Service recommendations for human immunodeficiency virus counseling and voluntary testing for pregnant women. Morb Mortal Wkly Rep - Recommendations and Reports. 1995;44(RR-7):1-15.
21 Department of Health and Human Services. Safety and toxicity of individual antiretroviral agents in pregnancy. Available at: http://aidsinfo.nih.gov/guidelines/perinatal/ST_022405.pdf. Accessed March 9, 2005.
22 Kourtis AP, Bulterys M, Nesheim SR, et al. Understanding the timing of HIV transmission from mother to infant. JAMA. 2001;285(6):709-712. [pmid: 11176886].
23 Read JS. American Academy of Pediatrics Committee on Pediatric A. Human milk, breastfeeding, and transmission of human immunodeficiency virus type 1 in the United States. American Academy of Pediatrics Committee on Pediatric AIDS. Pediatrics. 2003;112(5):1196-1205. [pmid: 14595069].
24 Dunn DT, Newell ML, Ades AE, et al. Risk of human immunodeficiency virus type 1 transmission through breastfeeding. Lancet. 1992;340(8819):585-588. [pmid: 1355163].
25 Nduati R. Breastfeeding and HIV-1 infection. A review of current literature. Adv Exp Med Biol. 2000;478:201-210. [pmid: 11065073].
26 The Breastfeeding and HIV International Transmission Study Group. Late postnatal transmission of HIV-1 in breastfed children: an individual patient data meta-analysis. J Infect Dis. 2004;189(12):2154-2166. [pmid: 15181561].
27 John GC, Richardson BA, Nduati RW, et al. Timing of breast milk HIV-1 transmission: a meta-analysis. East Afr Med J. 2001;78(2):75-79. [pmid: 11682950].
28 Leroy V, Newell ML, Dabis F, et al. International multicentre pooled analysis of late postnatal mother-to-child transmission of HIV-1 infection. Ghent International Working Group on Mother-to-Child Transmission of HIV. Lancet. 1998;352(9128):597-600. [pmid: 9746019].
29 Mofenson LM, Lambert JS, Stiehm ER, et al. Risk factors for perinatal transmission of human immunodeficiency virus type 1 in women treated with zidovudine. Pediatric AIDS Clinical Trials Group Study 185 Team. N Engl J Med. 1999;341(6):385-393. [pmid: 10432323].
30 Burns DN, Landesman S, Wright DJ, et al. Influence of other maternal variables on the relationship between maternal virus load and mother-to-infant transmission of human immunodeficiency virus type 1. J Infect Dis. 1997;175:1206-1210. [pmid: 9129087].
31 Shapiro DE, Sperling RS, Mandelbrot L, et al. Risk factors for perinatal human immunodeficiency virus transmission in patients receiving zidovudine prophylaxis. Pediatric AIDS Clinical Trials Group Protocol 076 Study Group. Obstet Gynecol. 1999;94(6):897-908. [pmid: 10576173].
32 Coll O, Hernandez M, Boucher CAB, et al. Vertical HIV-1 transmission correlates with a high maternal viral load at delivery. J Acquir Immune Defic Syndr. 1997;14(1):26-30.
33 Mayaux MJ, Dussiax E, Isopet J, et al. Maternal virus load during pregnancy and mother-to-child transmission of human immunodeficiency virus type. J Infect Dis. 1997;175(1):172-175. [pmid: 8985214].
34 Garcia PM, Kalish LA, Pitt J, et al. Maternal levels of plasma human immunodeficiency virus type 1 RNA and the risk of perinatal transmission. Women and Infants Transmission Study Group. N Engl J Med. 1999;341(6):394-402. [pmid: 10432324].
35 Grosch-Worner I, Schafer A, Obladen M, et al. An effective and safe protocol involving zidovudine and caesarean section to reduce vertical transmission of HIV-1 infection. AIDS. 2000;14(18):2903-2911. [pmid: 11153672].
36 Thea DM, Steketee RW, Pliner V, et al. The effect of maternal viral load on the risk of perinatal transmission of HIV-1. AIDS. 1997;11(4):437-444. [pmid: 9084790].
37 Cooper ER, Charurat M, Mofenson L, et al. Combination antiretroviral strategies for the treatment of pregnant HIV-1-infected women and prevention of perinatal HIV-1 transmission. J Acquir Immune Defic Syndr. 2002;29(5):484-494. [pmid: 11981365].
38 Simonds RJ, Steketee R, Nesheim S, et al. Impact of zidovudine use on risk and risk factors for perinatal transmission of HIV. Perinatal AIDS Collaborative Transmission Studies. AIDS. 1998;12:301-308. [pmid: 9517993].
39 European Collaborative Study. HIV-infected pregnant women and vertical transmission in Europe since 1986. AIDS. 2001;15(6):761-770. [pmid: 11371691].
40 Hershow RC, Riester KA, Lew J, et al. Increased vertical transmission of human immunodeficiency virus from hepatitis C virus-coinfected mothers. Women and Infants Transmission Study. J Infect Dis. 1997;176(2):414-420. [pmid: 9237706].
41 Landesman SH, Kalish LA, Burns DN, et al. Obstetrical factors and the transmission of human immunodeficiency virus type 1 from mother to child. The Women and Infants Transmission Study. N Engl J Med. 1996;334(25):1617-1623. [pmid: 8628356].
42 Van Dyke RB, Korber BT, Popek E, et al. The Ariel project: a prospective cohort study of maternal-child transmission of human immunodeficiency virus type 1 in the era of maternal antiretroviral therapy. J Infect Dis. 1999;179(2):319-328. [pmid: 9878014].
43 Turner BJ, Hauck WW, Fanning TR, et al. Cigarette smoking and maternal-child HIV transmission. J Acquir Immune Defic Syndr. 1997;14(4):327-337.
44 Mandelbrot L, Mayaux MJ, Bongain A, et al. Obstetric factors and mother-to-child transmission of human immunodeficiency virus type 1: The French perinatal cohorts. Am J Obstet Gynecol. 1996;175(3):661-667. [pmid: 8828431].
45 Boyer PJ, Dillon M, Navaie M, et al. Factors predictive of maternal-fetal transmission of HIV-1: preliminary analysis of zidovudine given during pregnancy and/or delivery. JAMA. 1994;271(24):1925-1930. [pmid: 7911164].
46 Bulterys M, Landesman S, Burns DN, et al. Sexual behavior and injection drug use during pregnancy and vertical transmission of HIV-1. J Acquir Immune Defic Syndr. 1997;15(1):76-82.
47 Newell ML, Dunn DT, Peckham CS, et al. Vertical transmission of HIV-1: maternal immune status and obstetric factors. The European Collaborative Study. AIDS. 1996;10(14):1675-1681. [pmid: 8970688].
48 The Italian Register for Human Immunodeficiency Virus Infection in Children. Determinants of mother-to-infant human immunodeficiency virus 1 transmission before and after the introduction of zidovudine prophylaxis. Arch Pediatr Adolesc Med. 2002;156(9):915-921. [pmid: 12197800].
49 Welles SL, Pitt J, Colgrove R, et al. HIV-1 genotypic zidovudine drug resistance and the risk of maternal-infant transmission in the Women and Infants Transmission Study Group. AIDS. 2000;14(3):263-271. [pmid: 10716502].
50 Bauer GR, Welles SL, Colgrove RR, et al. Zidovudine resistance phenotype and risk of perinatal HIV-1 transmission in zidovudine monotherapy-treated mothers with moderately advanced disease. J Acquir Immune Defic Syndr. 2003;34(3):312-319. [pmid: 14600578].
51 French R, Brocklehurst P. The effect of pregnancy on survival in women infected with HIV: a systematic review of the literature and meta-analysis. Br J Obstet Gynaecol. 1998;105(8):827-835. [pmid: 9746374].
52 Minkoff H, Hershow R, Watts DH, et al. The relationship of pregnancy to human immunodeficiency virus disease progression. Am J Obstet Gynecol. 2003;189(2):552-559. [pmid: 14520233].
53 Watts DH, Lambert J, Stiehm ER, et al. Progression of HIV disease among women following delivery. J Acquir Immune Defic Syndr. 2003;33(5):585-593. [pmid: 12902802].
54 Cao Y, Krogstad P, Korber BT, et al. Maternal HIV-1 viral load and vertical transmission of infection: the Ariel Project for the prevention of HIV transmission from mother to infant. Nat Med. 1997;3(5):549-552. [pmid: 9142125].
55 Melvin AJ, Burchett SK, Watts DH, et al. Effect of pregnancy and zidovudine therapy on viral load in HIV-1-infected women. J Acquir Immune Defic Syndr Hum Retrovirol. 1997;14(3):232-236. [pmid: 9117455].
56 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services, Chapter 28: Screening for Human Immunodeficiency Virus Infection. 1996. Available at: http://www.ahrq.gov/clinic/2ndcps/hiv.pdf. Accessed March 11, 2005.
57 Joint statement of the American Academy of Pediatrics and the American College of Obstetricians and Gynecologists. Human immunodeficiency virus screening. Pediatrics. 1999;104(1 Pt 1):128.
58 Institute of Medicine. Reducing the Odds: Preventing Perinatal Transmission of HIV in the United States. Washington, D. C.: National Academy Press; 1999.
59 Stiehm ER, Lambert JS, Mofenson LM, et al. Efficacy of zidovudine and human immunodeficiency virus (HIV) hyperimmune immunoglobulin for reducing perinatal HIV transmission from HIV-infected women with advanced disease: results of Pediatric AIDS Clinical Trials Group protocol 185. J Infect Dis. 1999;179(3):567-575. [pmid: 9952362].
60 Fawzi WW, Msamanga GI, Spiegelman D, et al. A randomized trial of multivitamin supplements and HIV disease progression and mortality. N Engl J Med. 2004;351:23-32. [pmid: 15229304].
61 Hirsch MS, Brun-Vezinet F, D'Aquila RT, et al. Antiretroviral drug resistance testing in adult HIV-1 infection: recommendations of an International AIDS Society-USA Panel. JAMA. 2000;283(18):2417-2426. [pmid: 10815085].
62 Avanti Steering Committee. Analysis of HIV-1 clinical trials: statistical magic?. Lancet. 1999;353(9169):2061-2064. [pmid: 10376634].
63 Fowler MG, Mofenson L, McConnell M. The interface of perinatal HIV prevention, antiretroviral drug resistance, and antiretroviral treatment: what do we really know?. J Acquir Immune Defic Syndr. 2003;34(3):308-311. [pmid: 14600577].
64 Nolan M, Fowler MG, Mofenson LM. Antiretroviral prophylaxis of perinatal HIV-1 transmission and the potential impact of antiretroviral resistance. J Acquir Immune Defic Syndr. 2002;30(2):216-229. [pmid: 12045685].
65 Eshleman SH, Mracna M, Guay LA, et al. Selection and fading of resistance mutations in women and infants receiving nevirapine to prevent HIV-1 vertical transmission (HIVNET 012). AIDS. 2001;15(15):1951-1957. [pmid: 11600822].
66 Cunningham CK, Chaix ML, Rekacewicz C, et al. Development of resistance mutations in women receiving standard antiretroviral therapy who received intrapartum nevirapine to prevent perinatal human immunodeficiency virus type 1 transmission: a substudy of Pediatric AIDS Clinical Trials Group protocol 316. J Infect Dis. 2002;186(2):181-188. [pmid: 12134253].
67 Centers for Disease Control and Prevention. Public Health Service Task Force recommendations for the use of antiretroviral drugs in pregnant women infected with HIV-1 for maternal health and for reducing perinatal HIV-1 transmission in the United States. Morb Mortal Wkly Rep—Recommendations and Reports. 1998;47(RR-2):1-30.
68 Harris RP, Helfand M, Woolf SH, et al. Current methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
69 Lindsay MK, Feng TI, Peterson HB, et al. Routine human immunodeficiency virus infection screening in unregistered and registered inner-city parturients. Obstet Gynecol. 1991;77(4):599-603. [pmid: 2002985].
70 Peterman TA, Todd KA, Mupanduki I. Opportunities for targeting publicly funded human immunodeficiency virus counseling and testing. J Acquir Immune Defic Syndr Hum Retrovirol. 1996;12(1):69-74. [pmid: 8624764].
71 Fehrs LJ, Fleming D, Foster LR, et al. Trial of anonymous versus confidential human immunodeficiency virus testing. Lancet. 1988;2(8607):379-382. [pmid: 2899784].
72 Barbacci MB, Dalabetta GA, Repke JT, et al. Human immunodeficiency virus infection in women attending an inner-city prenatal clinic: ineffectiveness of targeted screening. Sex Transm Dis. 1990;17(3):122-126. [pmid: 2247801].
73 Provisional Committee on Pediatric AIDS American Academy of Pediatrics. Perinatal human immunodeficiency virus testing. Pediatrics. 1995;95(2):303-307. [pmid: 7838655].
74 Samson L, King S. Evidence-based guidelines for universal counselling and offering of HIV testing in pregnancy in Canada. Can Med Assoc J. 1998;158(11):1449-1457. [pmid: 9629106]. [pmcid: 1229371].
75 Lewis R, O'Brien JM, Ray DT, et al. The impact of initiating a human immunodeficiency virus screening program in an urban obstetric population. Am J Obstet Gynecol. 1995;173(4):1329-1333. [pmid: 7485348].
76 Barbacci M, Repke JT, Chaisson RE. Routine prenatal screening for HIV infection. Lancet. 1991;337(8743):709-711. [pmid: 1672184].
77 Hawken J, Chard T, Jeffries DJ, et al. Evaluation of an antenatal HIV testing programme in an inner London health district. Br J Obstet Gynaecol. 1994;101(11):960-964. [pmid: 7999726].
78 Ellerbrock TV, Lieb S, Harrington PE, et al. Heterosexually transmitted human immunodeficiency virus infection among pregnant women in a rural Florida community. N Engl J Med. 1992;327(24):1704-1709. [pmid: 1308669].
79 Lindsay MK, Peterson HB, Feng TI, et al. Routine antepartum human immunodeficiency virus infection screening in an inner-city population. Obstetrics & Gynecology. 1989;74(3 Pt 1):289-294. [pmid: 2761902].
80 Fehrs LJ, Hill D, Kerndt PR, et al. Targeted HIV screening at a Los Angeles prenatal/family planning health center. Am J Public Health. 1991;81(5):619-622. [pmid: 2014863]. [pmcid: 1405093].
81 Landesman S, Minkoff H, Holman S, et al. Serosurvey of human immunodeficiency virus infection in parturients. Implications for human immunodeficiency virus testing programs of pregnant women. JAMA. 1987;258(19):2701-2703. [pmid: 3312662].
82 Mills WA, Martin DL, Bertrand JR, et al. Physicians' practices and opinions regarding prenatal screening for human immunodeficiency virus and other sexually transmitted diseases. Sex Transm Dis. 1998;25(3):169-175. [pmid: 9524996].
83 Connor EM, Sperling RS, Gelber R, et al. Reduction of maternal-infant transmission of human immunodeficiency virus type 1 with zidovudine treatment. Pediatric AIDS Clinical Trials Group Protocol 076 Study Group. N Engl J Med. 1994;331(18):1173-1180. [pmid: 7935654].
84 Centers for Disease Control and Prevention. Update: Perinatally acquired HIV/AIDS—United States, 1997. Morb Mortal Wkly Rep. 1997;46:1086-1092.
85 Centers for Disease Control and Prevention. Successful implementation of perinatal HIV prevention guidelines: a multistate surveillance evaluation. Morb Mortal Wkly Rep. 2001;50(RR-6):15-28.
86 Mercey D, Helps BA, Copas A, et al. Voluntary universal antenatal HIV testing. Br J Obstet Gynaecol. 1996;103(11):1129-1133. [pmid: 8917002].
87 Nichols SA, Bhatta MP, Lewis J, et al. Prenatal HIV counseling, testing and antiretroviral prophylaxis by obstetric and family medicine providers in Alabama. Am J Med Sci. 2002;324:305-309. [pmid: 12495296].
88 Centers for Disease Control and Prevention. Interpretation and use of the Western blot assay for serodiagnosis of human immunodeficiency virus type 1 infections. JAMA. 1989;262(24):3395-3397. [pmid: 2685380].
89 Centers for Disease Control and Prevention. Update: serologic testing for HIV-1 antibody—United States, 1988 and 1989. Morb Mortal Wkly Rep. 1990;39(22):380-383.
90 Celum CL, Coombs RW, Jones M, et al. Risk factors for repeatedly reactive HIV-1 EIA and indeterminate Western blots. Arch Intern Med. 1994;154(10):1129-1137. [pmid: 7910452].
91 Centers for Disease Control and Prevention. Update: HIV counseling and testing using rapid tests—United States, 1995. Morb Mortal Wkly Rep. 1998;47(11):211-215.
92 Centers for Disease Control and Prevention. Protocols for confirmation of reactive rapid HIV tests. Morb Mortal Wkly Rep. 2004;53(10):221-222.
93 World Health Organization. HIV simple/rapid assays: operational characteristics (phase I)—whole blood specimens. January 2002. Available at: http://www.who.int/bct/Main_areas_of_work/BTS/HIV_Diagnostics/Evaluation_reports/Rep12Draft220403.pdf. Accessed July 20, 2004.
94 Uni-Gold™ Recombigen® HIV (package insert; #045–138). Bray, Ireland: Trinity Biotech Plc.; rev. 03/04.
95 Reveal™ Rapid HIV-1 Antibody Test (package insert; #FDAINS0065). Halifax, Nova Scotia, Canada: MedMira Laboratories, Inc.; rev. 0/1.
96 Reynolds SJ, Ndongala LM, Luo CC, et al. Evaluation of a rapid test for the detection of antibodies to human immunodeficiency virus type 1 and 2 in the setting of multiple transmitted viral subtypes. Int J STD AIDS. 2002;13(3):171-173. [pmid: 11860693].
97 O'Connell RJ, Merritt TM, Malia JA, et al. Performance of the OraQuick rapid antibody test for diagnosis of human immunodeficiency virus type 1 infection in patients with various levels of exposure to highly active antiretroviral therapy. J Clin Microbiol. 2003;41(5):2153-2155. [pmid: 12734265]. [pmcid: 154669].
98 OraQuick® Rapid HIV-1 Antibody Test (package insert; #3001-0951). Bethlehem, PA: OraSure Technologies, Inc.; rev. 10/03.
99 Bulterys M, Jamieson DJ, O'Sullivan MJ, et al. Rapid HIV-1 testing during labor. JAMA. 2004;292(2):219-223. [pmid: 15249571].
100 Webber MP, Demas P, Enriquez E, et al. Pilot study of expedited HIV-1 testing of women in labor at an inner-city hospital in New York City. Am J Perinatol. 2001;18(1):49-57. [pmid: 11321245].
101 Ramalingam S, Kannangai R, Raj AA, et al. Rapid particle agglutination test for human immunodeficiency virus: hospital-based evaluation. J Clin Microbiol. 2002;40(4):1553-1554. [pmid: 11923395]. [pmcid: 140336].
102 Chalermchockcharoenkit A, Louisirirotchnakul S, Roongpisuthipong A, et al. Rapid human immunodeficiency virus diagnostic test during the intrapartum period in pregnant women who did not receive antenatal care. J Med Assoc Thai. 2002;85(6):703-708. [pmid: 12322844].
103 Lien TX, Tien NT, Chanpong GF, et al. Evaluation of rapid diagnostic tests for the detection of human immunodeficiency virus types 1 and 2, hepatitis B surface antigen, and syphilis in Ho Chi Minh City, Vietnam. Am J Trop Med Hyg. 2000;62(2):301-309. [pmid: 10813489].
104 Mashu A, Mbizvo MT, Makura E, et al. Evaluation of rapid on-site clinic HIV test, combined with counselling. AIDS. 1997;11(7):932-933. [pmid: 9189222].
105 Koblavi-Deme S, Maurice C, Yavo D, et al. Sensitivity and specificity of human immunodeficiency virus rapid serologic assays and testing algorithms in an antenatal clinic in Abidjan, Ivory Coast. J Clin Microbiol. 2001;39(5):1808-1812. [pmid: 11325995]. [pmcid: 88030].
106 Brattegaard K, Kouadio J, Adom ML, et al. Rapid and simple screening and supplemental testing for HIV-1 and HIV-2 infections in west Africa. AIDS. 1993;7(6):883-885. [pmid: 8395857].
107 Bhore AV, Sastry J, Patke D, et al. Sensitivity and specificity of rapid HIV testing of pregnant women in India. Int J STD AIDS. 2003;14(1):37-41. [pmid: 12590791].
108 Chirgwin KD, Feldman J, Dehovitz JA, et al. Incidence and risk factors for heterosexually acquired HIV in an inner-city cohort of women: temporal association with pregnancy. J Acquir Immune Defic Syndr. 1999;20:295-299.
109 Sansom SL, Jamieson DJ, Farnham PG, et al. Human immunodeficiency virus retesting during pregnancy: costs and effectiveness in preventing perinatal transmission. Obstet Gynecol. 2003;102(4):782-790. [pmid: 14551009].
110 Kleinman S, Busch MP, Hall L, et al. False-positive HIV-1 test results in a low-risk screening setting of voluntary blood donation. Retrovirus Epidemiology Donor Study. JAMA. 1998;280(12):1080-1085. [pmid: 9757856].
111 Sheon AR, Fox HE, Alexander G, et al. Misdiagnosed HIV infection in pregnant women: implications for clinical care. Public Health Rep. 1994;109(5):694-699. [pmid: 7938392]. [pmcid: 1403560].
112 Doran TI, Parra E. False-positive and indeterminate human immunodeficiency virus test results in pregnant women. Arch Fam Med. 2000;9(9):924-929. [pmid: 11031402].
113 Lester P, Partridge JC, Chesney MA, et al. The consequences of a positive prenatal HIV antibody test for women. J Acquir Immune Defic Syndr Hum Retrovirol. 1995;10(3):341-349. [pmid: 7552496].
114 Koenig LJ, Whitaker DJ, Royce RA, et al. Violence during pregnancy among women with or at risk for HIV infection. Am J Public Health. 2002;92(3):367-370. [pmid: 11867312]. [pmcid: 1447081].
115 Green L, Ardron C, Catalan J. HIV, childbirth and suicidal behaviour: a review. Hosp Med. 2000;61(5):311-314. [pmid: 10953735].
116 Nakchbandi IA, Longenecker JC, Ricksecker MA, et al. A decision analysis of mandatory compared with voluntary HIV testing in pregnant women. Ann Intern Med. 1998;128(9):760-767. [pmid: 9556471].
117 Lansky A, Jones JL, Frey RL, et al. Trends in HIV testing among pregnant women: United States, 1994-1999. Am J Public Health. 2001;91(8):1291-1293. [pmid: 11499121]. [pmcid: 1446763].
118 Irwin KL, Valdiserri RO, Holmberg SD. The acceptability of voluntary HIV antibody testing in the United States: a decade of lessons learned. AIDS. 1996;10(14):1707-1717. [pmid: 8970692].
119 Centers for Disease Control and Prevention. HIV testing among pregnant women—United States and Canada, 1998-2001. Morb Mortal Wkly Rep. 2002;51(45):1013-1016.
120 Fernandez MI, Wilson TE, Ethier KA, et al. Acceptance of HIV testing during prenatal care. Public Health Rep. 2000;115(5):460-468. [pmid: 11236018]. [pmcid: 1308602].
121 Royce RA, Walter EB, Fernandez MI, et al. Barriers to universal prenatal HIV testing in 4 US locations in 1997. Am J Public Health. 2001;91(5):727-733. [pmid: 11344880]. [pmcid: 1446691].
122 Simpson WM, Johnstone FD, Boyd FM, et al. A randomised controlled trial of different approaches to universal antenatal HIV testing: uptake and acceptability and Annex: Antenatal HIV testing—assessment of a routine voluntary approach. Health Technol Assess. 1999;3(4):1-112.
123 Lindsay MK, Adefris W, Peterson HB, et al. Determinants of acceptance of routine voluntary human immunodeficiency virus testing in an inner-city prenatal population. Obstet Gynecol. 1991;78(4):678-680. [pmid: 1923172].
124 Henderson SL, Lindsay MK, Higgins JE, et al. Experience with routine voluntary perinatal human immunodeficiency virus testing in an inner city hospital. Pediatr Infect Dis J. 2001;20(11):1090-1092. [pmid: 11734720].
125 Simpson WM, Johnstone FD, Boyd FM, et al. Uptake and acceptability of antenatal HIV testing: randomised controlled trial of different methods of offering the test. BMJ. 1998;316(7127):262-267. [pmid: 9472506]. [pmcid: 2665496].
126 Gibb DM, MacDonagh SE, Gupta R, et al. Factors affecting uptake of antenatal HIV testing in London: results of a multicentre study. BMJ. 1998;316(7127):259-261. [pmid: 9472505]. [pmcid: 2665481].
127 Stringer E, Stringer J, Cliver S, et al. Evaluation of a new testing policy for human immunodeficiency virus to improve screening rates. Obstet Gynecol. 2001;98(6):1104-1108. [pmid: 11755561].
128 Jayaraman GC, Preiksaitis JK, Larke B. Mandatory reporting of HIV infection and opt-out prenatal screening for HIV infection: effect on testing rates. Can Med Assoc J. 2003;168(6):679-682. [pmid: 12642422]. [pmcid: 154912].
129 Nolan M, Fowler MG, Mofenson LM. Antiretroviral prophylaxis of perinatal HIV-1 transmission and the potential impact of antiretroviral resistance. J Acquir Immune Defic Syndr. 2002;30(2):216-229. [pmid: 12045685].
130 Eastman PS, Shapiro DE, Coombs RW, et al. Maternal viral genotypic zidovudine resistance and infrequent failure of zidovudine therapy to prevent perinatal transmission of human immunodeficiency virus type 1 in Pediatric AIDS Clinical Trials Group Protocol 076. J Infect Dis. 1998;177(3):557-564. [pmid: 9498432].
131 Jourdain G, Ngo-Giang-Huong N, Le Coeur S, et al. Intrapartum exposure to nevirapine and subsequent maternal responses to nevirapine-based antiretroviral therapy. N Engl J Med. 2004;351(3):229-240. [pmid: 15247339].
132 Joo E, Carmack A, Garcia-Bunuel E, et al. Implementation of guidelines for HIV counseling and voluntary HIV testing of pregnant women. Am J Public Health. 2000;90(2):273-276. [pmid: 10667191]. [pmcid: 1446152].
133 Malonza IM, Richardson BA, Kreiss JK, et al. The effect of rapid HIV-1 testing on uptake of perinatal HIV-1 interventions: a randomized clinical trial. AIDS. 2003;17(1):113-118. [pmid: 12478076].
134 Centers for Disease Control and Prevention. Prenatal HIV testing and antiretroviral prophylaxis at an urban hospital—Atlanta, Georgia, 1997-2000. Morb Mortal Wkly Rep. 2004;52(5152):1245-1248.
135 Centers for Disease Control and Prevention. Progress toward elimination of perinatal HIV infection—Michigan, 1993-2000. Morb Mortal Wkly Rep. 2002;51(5):93-97.
136 Wade NA, Zielinski MA, Butsashvili M, et al. Decline in perinatal HIV transmission in New York State (1997-2000). J Acquir Immune Defic Syndr. 2004;36(5):1075-1082. [pmid: 15247561].
137 Fiscus SA, Adimora AA, Funk ML, et al. Trends in interventions to reduce perinatal human immunodeficiency virus type 1 transmission in North Carolina. Pediatr Infect Dis J. 2002;21(7):664-668. [pmid: 12237600].
138 Dominguez KL, Lindegren ML, D'Almada PJ, et al. Increasing trend of Cesarean deliveries in HIV-infected women in the United States from 1994 to 2000. J Acquir Immune Defic Syndr. 2003;33(2):232-238. [pmid: 12794560].
139 Garcia F, de Lazzari E, Plana M, et al. Long-term CD4+ T-cell response to highly active antiretroviral therapy according to baseline CD4+ T-cell count. J Acquir Immune Defic Syndr. 2004;36(2):702-713. [pmid: 15167289].
140 Wood E, Hogg RS, Yip B, et al. Is there a baseline CD4 cell count that precludes a survival response to modern antiretroviral therapy?. AIDS. 2003;17(5):711-720. [pmid: 12646794].
141 Re MC, Ramazzotti E, Manfredi R, et al. Viral load trend in HIV-1 seropositive patients with different CD4 cell counts before starting HAART. J Clin Virol. 2000;17(1):5-11. [pmid: 10814933].
142 Phillips AN, Staszewski S, Weber R, et al. HIV viral load response to antiretroviral therapy according to the baseline CD4 cell count and viral load. JAMA. 2001;286(20):2560-2567. [pmid: 11722270].
143 Kazempour K, Kammerman LA, Farr SS. Survival effects of ZDV, ddI, and ddC in patients with CD4 < or = 50 cells/mm3. J Acquir Immune Defic Syndr Hum Retrovirol. 1995;10(Suppl 2):S97-106. [pmid: 7552521].
144 Egger M, May M, Chene G, et al. Prognosis of HIV-1-infected patients starting highly active antiretroviral therapy: a collaborative analysis of prospective studies. Lancet. 2002;360(9327):119-129. [pmid: 12126821].
145 Working Group on Mother-To-Child Transmission of HIV. Rates of mother-to-child transmission of HIV-1 in Africa, America, and Europe: results from 13 perinatal studies. J Acquir Immune Defic Syndr. 1995;8(5):506-510.
146 Brocklehurst P. Interventions for reducing the risk of mother-to-child transmission of HIV infection (Cochrane Review). The Cochrane Library. Chichester, UK: John Wiley & Sons Ltd.; 2004.
147 Department of Health and Human Services. Recommendations for use of antiretroviral drugs in pregnant HIV-1-infected women for maternal health and interventions to reduce perinatal HIV-1 transmission in the United States. June 23, 2004. Available at: http://aidsinfo.nih.gov/guidelines/perinatal/PER_062304.pdf. Accessed 7/23/04.
148 Hitti J, Frenkel LM, Stek AM, et al. Maternal toxicity with continuous nevirapine in pregnancy: results from PACTG 1022. J Acquir Immune Defic Syndr. 2004;36(3):772-776. [pmid: 15213559].
149 European Collaborative Study. Mother-to-child transmission of HIV infection in the era of highly active antiretroviral therapy. Clin Infect Dis. 2005;40(3):458-465. [pmid: 15668871].
150 Mandelbrot L, Landreau-Mascaro A, Rekacewicz C, et al. Lamivudine-zidovudine combination for prevention of maternal-infant transmission of HIV-1. JAMA. 2001;285(16):2083-2093. [pmid: 11311097].
151 Dorenbaum A, Cunningham CK, Gelber RD, et al. Two-dose intrapartum/newborn nevirapine and standard antiretroviral therapy to reduce perinatal HIV transmission: a randomized trial. JAMA. 2002;288(2):189-198. [pmid: 12095383].
152 Lallemant M, Jourdain G, Le Coeur S, et al. Single-dose perinatal nevirapine plus standard zidovudine to prevent mother-to-child transmission of HIV-1 in Thailand. N Engl J Med. 2004;351(3):217-228. [pmid: 15247338].
153 Lallemant M, Jourdain G, Le Coeur S, et al. A trial of shortened zidovudine regimens to prevent mother-to-child transmission of human immunodeficiency virus type 1. N Engl J Med. 2000;343(14):982-991. [pmid: 11018164].
154 Shaffer N, Chuachoowong R, Mock PA, et al. Short-course zidovudine for perinatal HIV-1 transmission in Bangkok, Thailand: a randomised controlled trial. Bangkok Collaborative Perinatal HIV Transmission Study Group. Lancet. 1999;353(9155):773-780. [pmid: 10459957].
155 The Petra Study Team. Efficacy of three short-course regimens of zidovudine and lamivudine in preventing early and late transmission of HIV-1 from mother to child in Tanzania, South Africa, and Uganda (Petra study): a randomised, double-blind, placebo-controlled trial. Lancet. 2002;359(9313):1178-1186. [pmid: 11955535].
156 Wiktor SZ, Ekpini E, Karon JM, et al. Short-course oral zidovudine for prevention of mother-to-child transmission of HIV-1 in Abidjan, Cote d'Ivoire: a randomised trial. Lancet. 1999;353(9155):781-785. [pmid: 10459958].
157 Dabis F, Msellati P, Meda N, et al. 6-month efficacy, tolerance, and acceptability of a short regimen of oral zidovudine to reduce vertical transmission of HIV in breastfed children in Cote d'Ivoire and Burkina Faso: a double-blind placebo-controlled multicentre trial. DITRAME Study Group. Diminution de la Transmission Mere-Enfant. Lancet. 1999;353(9155):786-792. [pmid: 10459959].
158 Moodley D, Moodley J, Coovadia H, et al. A multicenter randomized controlled trial of nevirapine versus a combination of zidovudine and lamivudine to reduce intrapartum and early postpartum mother-to-child transmission of human immunodeficiency virus type 1. J Infect Dis. 2003;187(5):725-735. [pmid: 12599045].
159 Taha TE, Kumwenda NI, Gibbons A, et al. Short postexposure prophylaxis in newborn babies to reduce mother-to-child transmission of HIV-1: NVAZ randomised clinical trial. Lancet. 2003;362(9391):1171-1177. [pmid: 14568737].
160 Jackson JB, Musoke P, Fleming T, et al. Intrapartum and neonatal single-dose nevirapine compared with zidovudine for prevention of mother-to-child transmission of HIV-1 in Kampala, Uganda: 18-month follow-up of the HIVNET 012 randomised trial. Lancet. 2003;362(9387):859-868. [pmid: 13678973].
161 Taha TE, Kumwenda NI, Hoover DR, et al. Nevirapine and zidovudine at birth to reduce perinatal transmission of HIV in an African setting. JAMA. 2004;292(2):202-209. [pmid: 15249569].
162 Guay LA, Musoke P, Fleming T, et al. Intrapartum and neonatal single-dose nevirapine compared with zidovudine for prevention of mother-to-child transmission of HIV-1 in Kampala, Uganda: HIVNET 012 randomised trial. Lancet. 1999;354(9181):795-802. [pmid: 10485720].
163 Fowler MG, Newell ML. Breast-feeding and HIV-1 transmission in resource-limited settings. J Acquir Immune Defic Syndr. 2002;30(2):230-239. [pmid: 12045686].
164 Nduati R, John G, Mbori-Ngacha D, et al. Effect of breastfeeding and formula feeding on transmission of HIV-1: a randomized clinical trial. JAMA. 2000;283(9):1167-1174. [pmid: 10703779].
165 Coutsoudis A, Pillay K, Spooner E, et al. Influence of infant-feeding patterns on early mother-to-child transmission of HIV-1 in Durban, South Africa: a prospective cohort study. South African Vitamin A Study Group. Lancet. 1999;354(9177):471-476. [pmid: 10465172].
166 Mandelbrot L, Le Chenadec J, Berrebi A, et al. Perinatal HIV-1 transmission: interaction between zidovudine prophylaxis and mode of delivery in the French Perinatal Cohort. JAMA. 1998;280(1):55-60. [pmid: 9660364].
167 Maguire A, Sanchez E, Fortuny C, et al. Potential risk factors for vertical HIV-1 transmission in Catalonia, Spain: the protective role of cesarean section. The Working Group on HIV-1 Vertical Transmission in Catalonia. AIDS. 1997;11(15):1851-1857. [pmid: 9412704].
168 Dunn DT, Newell ML, Mayaux MJ, et al. Mode of delivery and vertical transmission of HIV-1: a review of prospective studies. Perinatal AIDS Collaborative Transmission Studies. J Acquir Immune Defic Syndr. 1994;7(10):1064-1066. [pmid: 8083824].
169 Towers CV, Deveikis A, Asrat T, et al. A “bloodless cesarean section” and perinatal transmission of the human immunodeficiency virus. Am J Obstet Gynecol. 1998;179(3 Pt 1):708-714. [pmid: 9757976].
170 The International Perinatal HIV Group. The mode of delivery and the risk of vertical transmission of human immunodeficiency virus type 1—a meta-analysis of 15 prospective cohort studies. N Engl J Med. 1999;340(13):977-987. [pmid: 10099139].
171 The European Mode of Delivery Collaboration. Elective caesarean-section versus vaginal delivery in prevention of vertical HIV-1 transmission: a randomised clinical trial. Lancet. 1999;353(9158):1035-1039. [pmid: 10199349].
172 Angelillo IF, Villari P. Meta-analysis of published studies or meta-analysis of individual data? Caesarean section in HIV-positive women as a study case. Public Health. 2003;117(5):323-328. [pmid: 12909421].
173 Ioannidis JP, Abrams EJ, Ammann A, et al. Perinatal transmission of human immunodeficiency virus type 1 by pregnant women with RNA virus loads <1000 copies/ml. J Infect Dis. 2001;183(4):539-545. [pmid: 11170978].
174 Davies G, Wilson RD, Desilets V, et al. Amniocentesis and women with hepatitis B, hepatitis C, or human immunodeficiency virus. JOGC. 2003;25(2):145-148. 149–152. [pmid: 12577132].
175 Shey Wiysonge CU, Brocklehurst P, Sterne JAC. Vaginal disinfection during labour for reducing the risk fo mother-to-child transmission of HIV infection (Cochrane Review). The Cochrane Library. Chichester, UK: John Wiley & Sons, Ltd.; 2004.
176 Bartlett JA, DeMasi R, Quinn J, et al. Overview of the effectiveness of triple combination therapy in antiretroviral-naive HIV-1 infected adults. AIDS. 2001;15(11):1369-1377. [pmid: 11504958].
177 Holman S, Berthaud M, Sunderland A, et al. Women infected with human immunodeficiency virus: counseling and testing during pregnancy. Semin Perinatol. 1989;13(1):7-15. [pmid: 2919292].
178 Weinhardt LS, Carey MP, Johnson BT, et al. Effects of HIV counseling and testing on sexual risk behavior: a meta-analytic review of published research, 1985-1997. Am J Public Health. 1999;89(9):1397-1405. [pmid: 10474559]. [pmcid: 1508752].
179 Wolitski RJ, MacGowan RJ, Higgins DL, et al. The effects of HIV counseling and testing on risk-related practices and help-seeking behavior. AIDS Educ Prev. 1997;9(Suppl B):52-67. [pmid: 9241398].
180 Bedimo AL, Bessinger R, Kissinger P. Reproductive choices among HIV-positive women. Soc Sci Med. 1998;46(2):171-179. [pmid: 9447641].
181 Lindsay MK, Grant J, Peterson HB, et al. The impact of knowledge of human immunodeficiency virus serostatus on contraceptive choice and repeat pregnancy. Obstet Gynecol. 1995;85(5 Pt 1):675-679. [pmid: 7724094].
182 Massad LS, Springer G, Jacobson L, et al. Pregnancy rates and predictors of conception, miscarriage and abortion in US women with HIV. AIDS. 2004;18(2):281-286. [pmid: 15075546].
183 Blair JM, Hanson DL, Jones JL, et al. Trends in pregnancy rates among women with human immunodeficiency virus. Obstet Gynecol. 2004;103(4):663-668. [pmid: 15051556].
184 Temmerman M, Moses S, Kiragu D, et al. Impact of single session post-partum counselling of HIV infected women on their subsequent reproductive behaviour. AIDS Care. 1990;2(3):247-252. [pmid: 2088520].
185 Selwyn PA, Carter RJ, Schoenbaum EE, et al. Knowledge of HIV antibody status and decisions to continue or terminate pregnancy among intravenous drug users. JAMA. 1989;261(24):3567-3571. [pmid: 2724503].
186 Brocklehurst P, Volmink J. Antiretrovirals for reducing the risk of mother-to-child transmission of HIV infection (Cochrane Review). The Cochrane Library. Chichester, UK: John Wiley & Sons, Ltd.; 2003.
187 Watts DH, Balasubramanian R, Maupin RT Jr, et al. Maternal toxicity and pregnancy complications in human immunodeficiency virus-infected women receiving antiretroviral therapy: PACTG 316. Am J Obstet Gynecol. 2004;190(2):506-516. [pmid: 14981398].
188 Justman JE, Benning L, Danoff A, et al. Protease inhibitor use and the incidence of diabetes mellitus in a large cohort of HIV-infected women. J Acquir Immune Defic Syndr. 2003;32(3):298-302. [pmid: 12626890].
189 Chmait R, Franklin P, Spector SA, et al. Protease inhibitors and decreased birth weight in HIV-infected pregnant women with impaired glucose tolerance. J Perinatol. 2002;22(5):370-373. [pmid: 12082471].
190 Morris AB, Cu-Uvin S, Harwell JI, et al. Multicenter review of protease inhibitors in 89 pregnancies. J Acquir Immune Defic Syndr. 2000;25(4):306-311. [pmid: 11114830].
191 Edwards SG, Larbalestier N, Hay P, et al. Experience of nevirapine use in a London cohort of HIV-infected pregnant women. HIV Med. 2001;2(2):89-91. [pmid: 11737384].
192 Lyons F, Hopkins S, Mc Geary A, et al. Nevirapine tolerability in HIV infected women in pregnancy—a word of caution. Paper presented at: 2nd IAS Conference on HIV Pathogenesis and Treatment, 2003; Paris.
193 Bardeguez AD, Shapiro DE, Mofenson LM, et al. Effect of cessation of zidovudine prophylaxis to reduce vertical transmission on maternal HIV disease progression and survival. J Acquir Immune Defic Syndr. 2003;32(2):170-181. [pmid: 12571527].
194 Sperling RS, Shapiro DE, McSherry GD, et al. Safety of the maternal-infant zidovudine regimen utilized in the Pediatric AIDS Clinical Trial Group 076 Study. AIDS. 1998;12(14):1805-1813. [pmid: 9792381].
195 Morris L, Pillay C, Chezzi C, et al. Low frequency of the V106M mutation among HIV-1 subtype C-infected pregnant women exposed to nevirapine. AIDS. 2003;17(11):1698-1700. [pmid: 12853755].
196 Rodriguez EJ, Spann C, Jamieson D, et al. Postoperative morbidity associated with cesarean delivery among human immunodeficiency virus-seropositive women. Am J Obstet Gynecol. 2001;184(6):1108-1111. [pmid: 11349171].
197 Semprini AE, Castagna C, Ravizza M, et al. The incidence of complications after caesarean section in 156 HIV-positive women. AIDS. 1995;9(8):913-917. [pmid: 7576327].
198 Watts DH, Lambert JS, Stiehm ER, et al. Complications according to mode of delivery among human immunodeficiency virus-infected women with CD4 lymphocyte counts of < or = 500/microL. Am J Obstet Gynecol. 2000;183(1):100-107. [pmid: 10920316].
199 Read JS, Tuomala R, Kpamegan E, et al. Mode of delivery and postpartum morbidity among HIV-infected women: the women and infants transmission study. J Acquir Immune Defic Syndr. 2001;26(3):236-245. [pmid: 11242196].
200 Marcollet A, Goffinet F, Firtion G, et al. Differences in postpartum morbidity in women who are infected with the human immunodeficiency virus after elective cesarean delivery, emergency cesarean delivery, or vaginal delivery. Am J Obstet Gynecol. 2002;186(4):784-789. [pmid: 11967508].
201 Taylor GP, Low-Beer N. Antiretroviral therapy in pregnancy: a focus on safety. Drug Saf. 2001;24(9):683-702. [pmid: 11522121].
202 Brocklehurst P, French R. The association between maternal HIV infection and perinatal outcome: a systematic review of the literature and meta-analysis. Br J Obstet Gynaecol. 1998;105:836-848. [pmid: 9746375].
203 Tuomala RE, Shapiro DE, Mofenson LM, et al. Antiretroviral therapy during pregnancy and the risk of an adverse outcome. N Engl J Med. 2002;346(24):1863-1870. [pmid: 12063370].
204 European Collaborative Study. Exposure to antiretroviral therapy in utero or early life: the health of uninfected children born to HIV-infected women. J Acquir Immune Defic Syndr. 2003;32(4):380-387. [pmid: 12640195].
205 Poirier MC, Divi RL, Al-Harthi L, et al. Long-term mitochondrial toxicity in HIV-uninfected infants born to HIV-infected mothers. J Acquir Immune Defic Syndr. 2003;33(2):175-183. [pmid: 12794551].
206 Divi RL, Walker VE, Wade NA, et al. Mitochondrial damage and DNA depletion in cord blood and umbilical cord from infants exposed in utero to Combivir. AIDS. 2004;18(7):1013-1021. [pmid: 15096804].
207 Blanche S, Tardieu M, Rustin P, et al. Persistent mitochondrial dysfunction and perinatal exposure to antiretroviral nucleoside analogues. Lancet. 1999;354(9184):1084-1089. [pmid: 10509500].
208 Barret B, Tardieu M, Rustin P, et al. Persistent mitochondrial dysfunction in HIV-1-exposed but uninfected infants: clinical screening in a large prospective cohort. AIDS. 2003;17(12):1769-1785. [pmid: 12891063].
209 Alimenti A, Burdge DR, Ogilvie GS, et al. Lactic acidemia in human immunodeficiency virus-uninfected infants exposed to perinatal antiretroviral therapy. Pediatr Infect Dis J. 2003;22(9):782-789. [pmid: 14506368].
210 The Perinatal Safety Review Working G. Nucleoside exposure in the children of HIV-infected women receiving antiretroviral drugs: absence of clear evidence for mitochondrial disease in children who died before 5 years of age in five United States cohorts. J Acquir Immune Defic Syndr. 2000;25(3):261-268. [pmid: 11115957].
211 Lindegren ML, Rhodes P, Gordon L, et al. Drug safety during pregnancy and in infants. Lack of mortality related to mitochondrial dysfunction among perinatally HIV-exposed children in pediatric HIV surveillance. Ann N Y Acad Sci. 2000;918:222-235. [pmid: 11131709].
212 Bulterys M, Nesheim S, Abrams EJ, et al. Lack of evidence of mitochondrial dysfunction in the offspring of HIV-infected women. Retrospective review of perinatal exposure to antiretroviral drugs in the Perinatal AIDS Collaborative Transmission Study. Ann N Y Acad Sci. 2000;918:212-221. [pmid: 11131707].
213 Dominguez K, Bertolli J, Fowler M, et al. Lack of definitive severe mitochondrial signs and symptoms among deceased HIV-uninfected and HIV-indeterminate children < or = 5 years of age, Pediatric Spectrum of HIV Disease project (PSD), USA. Ann N Y Acad Sci. 2000;918:236-246. [pmid: 11131710].
214 Culnane M, Fowler M, Lee SS, et al. Lack of long-term effects of in utero exposure to zidovudine among uninfected children born to HIV-infected women. JAMA. 1999;281(2):151-157. [pmid: 9917118].
215 Hanson IC, Antonelli TA, Sperling RS, et al. Lack of tumors in infants with perinatal HIV-1 exposure and fetal/neonatal exposure to zidovudine. J Acquir Immune Defic Syndr Hum Retrovirol. 1999;20(5):463-467. [pmid: 10225228].
216 Dunn DT, Peckham CS, Semprini AE, et al. Vertical transmission of HIV-1: maternal immune status and obstetric factors. The European Collaborative Study. AIDS. 1996;10:1675. [pmid: 8970688].
217 Dickover RE, Garratty EM, Herman SA, et al. Identification of levels of maternal HIV-1 RNA associated with risk of perinatal transmission. Effect of maternal zidovudine treatment on viral load. JAMA. 1996;275(8):599-605. [pmid: 8594240].
218 The Italian Collaborative Study on HIV Infection in Pregnancy. Mother-to-child transmission of human immunodeficiency virus in Italy: temporal trends and determinants of infection. Hum Reprod. 1999;14(1):242–246.
219 McGowan JP, Crane M, Wiznia AA, et al. Combination antiretroviral therapy in human immunodeficiency virus-infected pregnant women. Obstet Gynecol. 1999;94(5):641-646. [pmid: 10546703].
220 Matheson PB, Thomas PA, Abrams EJ, et al. Heterosexual behavior during pregnancy and perinatal transmission of HIV-1. AIDS. 1996;10:1249-1256. [pmid: 8883587].
221 Rodriguez EM, Mofenson LM, Chang BH, et al. Association of maternal drug use during pregnancy with maternal HIV culture positivity and perinatal HIV transmission. AIDS. 1996;10:273-282. [pmid: 8882667].
222 Burns DN, Landesman S, Munez LR, et al. Cigarette smoking, premature rupture of membranes, and vertical transmission of HIV-1 among women with low CD4^+^ levels. J Acquir Immune Defic Syndr. 1994;7:718-726. [pmid: 7911527].
223 The European Collaborative Study, Swiss Mother + Child HIV Cohort Study. Combination antiretroviral therapy and duration of pregnancy. AIDS. 2000;14(18):2913-2920. [pmid: 11398741].