# Acknowledgments

This Evidence Synthesis was funded by the Agency for Healthcare Research and Quality (AHRQ) for the U.S. Preventive Services Task Force (USPSTF), and the investigators acknowledge the contributions of Gurvaneet Randhawa, MD, MPH, Task Order Officer, AHRQ, and David Lanier, MD, Medical Officer, AHRQ. Members of the USPSTF who served as leads for this project include: Janet Allen, PhD, RN, CS, FAAN; Ned Calonge, MD, MPH; Albert Siu, MD, MSPH; Diana Petitti, MD, MPH; and Mark Johnson, MD, MPH. The investigators thank Mark Helfand, MD, MS, for serving as a consultant; expert reviewers listed in Appendix F of this report for commenting on draft versions; Andrew Hamilton, MLS, MS, for conducting the literature searches; Rongwei Fu, PhD, for performing the statistical analyses; and Kim Villemyer and Christina Bougatsos for assisting with the manuscript.

## Request for Reprints

Reprints are available from the AHRQ Web site at www.ahrq.gov (click on Preventive Services) and in print through the AHRQ Publications Clearinghouse (call1-800-358-9295).