# Discussion

## Summary of Evidence

There is no direct evidence on benefits of screening for HIV infection in pregnant women. Other evidence obtained for the systematic review is summarized in Table 15. It indicates the study design and the quality of evidence for each key question. Briefly, universal screening identifies significantly more HIV-infected pregnant women than targeted screening. HIV tests are extremely accurate and recommended interventions markedly reduce the risk of mother-to-child transmission of HIV infection. Currently recommended interventions appear to be associated with high benefit-to-harm ratios.

Table 15 Summary of Findings of Systematic Evidence Review of HIV Screening for Pregnant Women

Arrow | Key question | Level and type of evidence | Overall evidence for the link | Findings
1 | Does screening for HIV in asymptomatic pregnant women reduce mother-to-child transmission or premature death and disability? | None | Not applicable | No controlled studies or observational studies link screening directly to health outcomes.
2 | Can clinical or demographic characteristics (including persons in specific settings) identify subgroups of asymptomatic pregnant women at increased risk for HIV infection compared to the general population of pregnant women? | II-2. Cohort and cross-sectional studies | FAIR | The strongest risk factors for HIV infection from multiple large observational studies are high-risk sexual behaviors and intravenous drug use. Observational studies from before 1995 found that 8%-58% of HIV-positive pregnant women reported identifiable risk factors, but often did not assess the number of unprotected sexual partners. Universal counseling and voluntary screening appears to increase the yield of HIV diagnoses compared to targeted screening. In a seven-state surveillance study, the proportion of HIV-infected women diagnosed before delivery increased from 70% to 80% after the introduction of universal counseling.
3 | What are the test characteristics of HIV antibody test strategies in pregnant women? | Studies of diagnostic test accuracy | GOOD for standard and rapid tests (OraQuick®) | Standard testing is associated with a sensitivity and specificity of >99%. One study of Oraquick® rapid testing in women with unknown HIV status presenting to labor and delivery units found similar accuracy, but data from clinical settings are limited for other FDA-approved rapid tests. Other screening technologies (home sampling, oral and urine specimens) have not been well studied in pregnant women.
| | | POOR for other screening methods
4 | What are the harms (including labeling and anxiety) associated with screening? Is screening acceptable to pregnant women? | Studies of diagnostic test accuracy | GOOD for false-positive rates and false-negative rates | False-positive results appear rare with standard testing, even in low-prevalence settings. Indeterminate test results may be slightly more common in pregnant or parous women. False-positive tests from rapid tests could occur if results are given prior to confirmatory testing. In a labor and delivery setting, 4 out of 4,849 pregnant women briefly received unnecessary interventions after initial false-positive rapid test results in one study. False-negative results could occur during the window period before seroconversion and provide false reassurance. True-negative tests could also provide false reassurance in patients practicing high-risk behaviors.
| | II-2. Cohort and cross-sectional studies for harms of screening and acceptability | FAIR to GOOD for harms from screening and acceptability of testing | True-positive tests are associated with social consequences, anxiety, and labeling, but these harms are difficult to measure. A recent good-quality cohort study found that the rate of violence during pregnancy was similar between HIV-infected women and matched controls.
| | | | Risks of partner dissolution, and suicide risk have not been well studied in pregnant women.
| | | | A good-quality systematic review found that acceptance rates for voluntary HIV antibody testing among pregnant women ranged widely from 23% to 100%. Testing rates appeared to be higher in states and provinces that used an ‘opt-out’ (pregnant women are informed that an HIV test is being conducted as a standard part of prenatal care and that they may refuse it) compared to an ‘opt-in’ (pregnant women are required to consent specifically to an HIV test) policy (71% to 98% vs. 25% to 83%, respectively). Rapid tests in labor and delivery units were associated with an acceptance rate of 84% in a good-quality prospective study. Over 90% of tested pregnant women returned for results in one large U.S. study.
5 | How many HIV-infected pregnant women who meet criteria for interventions receive them? | II-2. Cohort and cross-sectional studies | FAIR for CD4 count at time of diagnosis | All HIV-infected pregnant women are eligible for antiretroviral prophylaxis to reduce the risk of mother-to-child transmission. Eligibility for antiretroviral treatment (to improve maternal outcomes) is determined by CD4 count and viral loads. One large U.S. cohort study found that 13% (70/546) of HIV-infected pregnant women had a CD4 count <200 cells/mm^3^, which could affect the choice of long-term maternal antiretroviral therapy.
| | | GOOD for acceptability of interventions | Antiretroviral prophylaxis and other strategies for reduction of mother-to-child transmission appear to be widely acceptable to pregnant women, with more than 90% of HIV-positive women receiving antiretrovirals during pregnancy, and an increasing proportion (58%-80%) receiving combination regimens. 37%-50% of women with known HIV infection underwent elective cesarean section since 1998 in the United States.
6 | What are the harms associated with the work-up for HIV infection in pregnant women? | None | Not applicable | No evidence
7a | 1) How effective is antiretroviral prophylaxis (to prevent mother-to-child transmission) or treatment (to improve maternal outcomes) in reducing transmission rates or improving clinical outcomes (mortality, functional status, quality of life, symptoms, or opportunistic infections) in pregnant women with HIV infection? | I, II-2. Randomized controlled trial, large cohort studies | GOOD | A good-quality clinical trial (PACTG 076) found that 3-part zidovudine prophylaxis decreased mother-to-child transmission from 25% to 8%. Large observational studies found that antiretroviral regimens with more drugs were superior to regimens with fewer drugs for reducing mother-to-child transmission. A large, good-quality observational study found that HAART significantly reduced mother-to-child transmission compared to no antiretroviral therapy (adjusted odds ratio 0.13, 95% confidence interval 0.06 to 0.27). A recent good-quality randomized trial of slightly shortened zidovudine plus single doses of nevirapine found rates of transmission (1.9%) comparable to those of full-course combination antiretroviral regimens. Other short courses of antiretroviral prophyhlaxis were less effective than full courses, but could be useful in HIV-infected women diagnosed late in pregnancy. There were insufficient data to estimate long-term effects of antiretrovirals started during pregnancy and either continued or interrupted.
7a | 2) How effective is avoidance of breastfeeding in reducing mother-to-child transmission rates in pregnant women with HIV infection? | I, II-2. Randomized controlled trial, cohort studies | GOOD | In two meta-analyses, breastfeeding was associated with an increase in overall absolute rate of vertical transmission of 14% and 16%. One African randomized controlled trial found that breastfeeding reduced the probability of vertical transmission at 24 months from 37% to 20%. One European observational study in women who received antiretroviral treatment found that breastfeeding significantly increased rates of mother-to-child transmission (OR 10.20, 95% CI, 2.73, 38.11).
7a | 3) How effective is elective cesarean section or other labor management practices in reducing mother-to-child transmission rates in pregnant women with HIV infection? | I, II-2. Randomized controlled trial and meta-analysis of cohort studies | GOOD | One good-quality European cohort study evaluated the effectiveness of elective cesarean section in the HAART era. It found an odds ratio of 0.33 (95% CI 0.11 to 0.94) for mother-to-child transmission with elective cesarean section compared to vaginal delivery when adjusted for other factors including antiretroviral therapy and maternal viral load. Other studies were conducted prior to the widespread use of HAART. One good-quality randomized controlled trial found that elective cesarean section reduced the rate of mother-to-child transmission of HIV from 10.5% to 1.8%. A meta-analysis of 15 cohort studies found that elective cesarean section reduced the risk of vertical transmission compared to other modes of delivery (OR 0.43, 95% CI, 0.33, 0.56). Elective cesarean section appeared effective in women with viral loads <1000 copies/ml, but transmission rates were very low with antiretroviral treatment alone (about 1%).
| | | | The effectiveness of other labor management practices has not been well studied.
7a | 4) How effective is counseling on risky behaviors in reducing mother-to-child transmission rates in pregnant women with HIV infection? | None | Not applicable | No evidence
7a | 5) How effective are immunizations, routine monitoring and follow-up, or prophylaxis for opportunistic infections in reducing mother-to-child transmission rates or improving clinical outcomes in pregnant women with HIV infection? | None | Not applicable | No evidence specifically in pregnant women
7b | Does immediate antiretroviral treatment in HIV-infected pregnant women result in improvements in clinical outcomes compared to delayed treatment until symptomatic? | None | Not applicable | We identified no studies estimating the effects of delayed or discontinued versus continuous HAART in HIV-infected women identified during pregnancy. We also identified no studies examining the effects of withholding first trimester antiretrovirals on mother-to-child transmission rates or other clinical outcomes.
7c | How well do interventions reduce the rate of viremia, improve CD4 counts, or reduce risky behaviors? How does identification of HIV infection in pregnant women affect future reproductive choices? | I, II-2. Randomized controlled trials, cohort studies | GOOD | HAART is highly effective in reducing viral loads and increasing CD4 counts in pregnant women. There is insufficient evidence to determine the effects of HIV diagnosis during pregnancy on risky behaviors associated with vertical or horizontal transmission. Tubal ligation rates among HIV-infected pregnant women were 24% to 27% in three studies, and may be higher than in HIV-negative controls. Abortion rates do not appear higher among HIV-infected compared to uninfected women. There were insufficient data to determine the effects of HIV diagnosis during pregnancy on other future reproductive choices (pregnancy rates, contraceptive use).
8 | What are the harms associated with antiretroviral drugs (including adverse effects from in utero exposure) and elective cesarean section? | I, II-2. Randomized controlled trials, cohort studies | GOOD | Antiretroviral exposure during pregnancy is associated with significant non-obstetric adverse events for the mother, but these are usually short-term and resolve after stopping or changing the offending drug or drug combination. Serious or fatal maternal events appear rare on zidovudine alone and currently recommended combination regimens. One recent randomized controlled trial of combination antiretrovirals was discontinued early (N=38) because of a high rate of treatment-limiting hepatitis or cutaneous toxicity with continuous nevirapine (29%) compared to nelfinavir (5%) in combination with zidovudine. Another trial found lower 6-month virologic response rates (49% versus 68%) after maternal exposure to a single dose of peripartum nevirapine and continuous nevirapine-based treatment after delivery. We identified no studies evaluating the effects of limited exposure to combination antiretrovirals during pregnancy on subsequent long-term clinical progression or response to later antiretroviral therapy.
| | | | Cohort studies have found a higher rate of postpartum complications in HIV-infected women who underwent cesarean section compared to HIV-infected women who delivered vaginally. The largest study found a relative risk of 2.62 (95% CI, 1.61, 4.20) compared to vaginal delivery.
| | | | No increase in any specific fetal abnormality has been identified with currently recommended antiretroviral regimens, but there are relatively little data on the in utero safety of antiretroviral regimens. Evidence regarding the association between combination antiretrovirals and premature delivery was mixed. Cohort studies of infants exposed to zidovudine in utero have found no evidence of long-term complications up to 6 years after exposure.
9 | Have improvements in intermediate outcomes (CD4 counts, viremia, or risky behaviors) in HIV-infected pregnant women been shown to improve clinical outcomes or reduce mother-to-child transmission? | II-2. Cohort and cross-sectional studies | GOOD for viral loads | Reduced viral loads have been consistently associated with reduced rates of mother-to-child transmission of HIV in clinical trials and observational studies. Several behaviors (unprotected intercourse, smoking, hard drug use) are associated with an increased risk of vertical transmission, but we identified no studies evaluating the association between changes in these behaviors and subsequent mother-to-child transmission rates.
| | | POOR for behavior changes

HAART, highly active retroviral therapy.

## Outcomes Table

Table 16 estimates the outcomes from screening prior to the third trimester in three hypothetical cohorts (0.15% prevalence, 0.30% prevalence, and high risk) of 10,000 pregnant women, using the highest quality and most applicable available evidence. We did not include areas in this table in which reliable data to estimate the clinical magnitude of benefit or harm were not available, such as harms from screening (anxiety, labeling, violence, suicide, partnership dissolution) or decreased horizontal transmission from counseling. We focused on the benefits of receipt of combination antiretroviral regimens on the risk of mother-to-child transmission, as this intervention has the greatest impact on transmission rates, and there were insufficient or limited data on other clinical outcomes (such as long-term maternal outcomes or horizontal transmission rates) or benefits associated with other interventions such as prophylaxis for opportunistic infections, counseling on risky behaviors, immunizations, routine monitoring and follow-up, or additional benefits from elective cesarean section in women receiving HAART. For harms of interventions, we focused on the rate of postpartum complications from elective cesarean section, as studies have not shown clear evidence of long-term infant adverse events from exposure to antiretrovirals, and there are insufficient data regarding the risks of antiretroviral exposure on long-term maternal outcomes. We calculated numbers needed to screen and treat to prevent one case of maternal-to-child transmission and cause one postpartum complication (postpartum fever, endometritis, hemorrhage, or urinary tract infection) from elective cesarean section (Appendix E).

Table 16 Outcome Table of Screening for HIV Infection in 10,000 Asymptomatic Pregnant Women

Variable | 0.15% prevalence | 0.30% prevalence | High risk | Source
Base-case assumptions
Prevalence of HIV infection | 0.15% | 0.30% | 5% | CDC, 2002^10^
| | | | Lindegren et al, 1999^5^
| | | | Fehrs et al, 1988^71^
| | | | Barbacci et al, 1990^72^
Accuracy of standard testing | 99%+ | 99%+ | 99%+ | CDC, 1990^89^
| | | | CDC, 1998^67^
Proportion receiving test results | 91% | 91% | 91% | Joo, 2000^132^
Proportion receiving antiretroviral therapy | 60%-90% | 60–90% | 60–90% | CDC, 2004^134^
| | | | CDC, 2002^135^
| | | | Wade et al, 2004^136^
| | | | Fiscus et al, 2002^137^
| | | | Cooper et al, 2002^37^
Proportion receiving elective cesarean section | 37–50% | 37–50% | 37–50% | Fiscus et al, 2002^137^
| | | | Dominguez et al, 2003^138^
| | | | CDC, 2004^134^
Rate of mother-to-child transmission in absence of interventions | 14–25% | 14–25% | 14–25% | Working Group on Mother-to-Child Transmission of HIV, 1995^145^
Relative risk for mother-to-child-transmission with HAART compared to no antiretrovirals | 0.13 (95% CI, 0.06 to 0.27) | 0.13 (95% CI, 0.06 to 0.27) | 0.13 (95% CI, 0.06 to 0.27) | European Collaborative Study, 2005^149^
Rate of postpartum complications in HIV-infected women delivering vaginally | 10.3% (95% CI, 8.39 to 12.6) | 10.3% (95% CI, 8.39 to 12.6) | 10.3% (95% CI, 8.39 to 12.6) | Read et al, 2001^199^
Relative risk of postpartum complications from elective cesarean section | 2.62 (95% CI, 1.61 to 4.20) | 2.62 (95% CI, 1.61 to 4.20) | 2.62 (95% CI, 1.61 to 4.20) | Read, 2001^199^
Results
Number identified as positive | 15.0000 | 30.0000 | 500.0000
Number receiving test results | 13.6000 | 27.3000 | 455.0000
Number of cases of mother-to-child transmission expected without interventions among women receiving test results | 1.9–3.4 | 3.8–6.8 | 64–114
Number receiving combination antiretroviral therapy | 8.2–12.3 | 16.4–24.6 | 273–410
Number receiving elective cesarean section | 5.0–6.8 | 10.1–13.6 | 168–228
Number of cases of mother-to-child transmission prevented with HAART | 1.0 (95% CI, 0.8 to 1.1) – 2.7 (95% CI, 2.2 to 2.8) | 2.0 (95% CI, 1.6 to 2.1) – 5.3 (95% CI, 4.4 to 5.7) | 33 (95% CI, 27 to 36) – 88 (95% CI, 73 to 95)
Number needed to screen to prevent 1 case of mother-to-child transmission of HIV with HAART | 3780 (95% CI, 3500 to 4549) – 10120 (95% CI, 9380 to 12170) | 1890 (95% CI, 1750 to 2270) – 5060 (95% CI, 4690 to 6090) | 113 (95% CI, 105 to 136) – 304 (95% CI, 282 to 365)
Number needed to treat with interventions to prevent 1 case of mother-to-child transmission of HIV with HAART | 4.6 (95% CI, 4.3 to 5.5) – 8.2 (95% CI, 7.6 to 9.9) | 4.6 (95% CI, 4.3 to 5.5) – 8.2 (95% CI, 7.6 to 9.9) | 4.6 (95% CI, 4.3 to 5.5) – 8.2 (95% CI, 7.6 to 9.9)
Number of postpartum complications caused by elective cesarean section | 0.8 (95% CI, 0.3 to 1.7) – 1.1 (95% CI, 0.4 to 2.3) | 1.7 (95% CI, 0.6 to 3.5) –2.3 (95% CI, 0.8 to 4.7) | 28 (95% CI, 11 to 58) – 38 (95% CI, 14 to 78)
Number needed to screen to cause 1 postpartum complication from elective cesarean section | 8810 (95% CI, 4280 to 23420) –11910 (95% CI, 5780 to 31640) | 4400 (95% CI, 2140 to 11700) – 5950 (95% CI, 2880 to 15820) | 260 (95% CI, 130 to 700) –357 (95% CI, 170 to 940)
Number needed to treat to cause 1 postpartum complication from elective cesarean section | 6.0 (95% CI, 2.9 to 15.9) | 6.0 (95% CI, 2.9 to 15.9) | 6.0 (95% CI, 2.9 to 15.9)

HAART, highly active antiretroviral therapy.

To estimate the benefits of counseling and screening for HIV infection in pregnant women, we made several assumptions. We used recent estimates of rates of combination antiretroviral regimens (60%-90%)^37,^ ^134^–^137^ and elective cesarean section (37%-50%) utilization by HIV-infected pregnant women in the U.S.^134,^ ^137,^ ^138^ Our estimates of the effectiveness of interventions were conservative and did not include potential benefits from elective cesarean section or avoidance of breastfeeding in women receiving combination therapy.^48^ We also did not include potential benefits from screening on long-term maternal outcomes.

Numbers needed to screen to prevent one case of infant HIV infection ranged from 3,500 to 12,170 in the low-risk population to 105 to 365 in high-risk women. The number needed to treat with interventions to prevent one case of infant HIV infection was 4.3–9.9. The number needed to screen to cause one postpartum complication from elective cesarean section ranged from 4,280 to 31,640 in the low-risk population to 130 to 940 in the high-risk population. The number needed to treat to cause one postpartum complication from elective cesarean section was about 6 (95% CI, 2.9 to 15.9).

## Conclusions

There are no published trials directly linking screening for HIV in pregnant women with clinical outcomes. In developed countries, the rate of mother-to-child transmission from untreated HIV-infected women ranges from 14% to 25%. Targeted screening of pregnant women with risk factor assessment would miss a significant proportion of infected persons. Standard office-based testing is highly (>99%) sensitive and specific, and initial studies of rapid HIV tests in labor and delivery settings found similar diagnostic accuracy. HIV testing rates during pregnancy continue to vary widely in the U.S. and appear to be higher in states using ‘opt-out’ testing policies. Recommended interventions (antiretroviral prophylaxis, elective cesarean section in selected patients, and avoidance of breastfeeding) are associated with transmission rates of 1%-2% in clinical trials and large observational studies. Shorter regimens are less effective, but also decrease the rate of transmission. The estimated benefits from combination antiretroviral regimens appear to greatly outweigh the risk of short-term complications, but long-term follow-up is not yet available. Elective cesarean section is associated with an increased risk of mostly short-term maternal adverse events. There are insufficient data to estimate the effects of interventions during pregnancy on long-term maternal disease progression or other outcomes (such as horizontal transmission).

## Limitations of the Literature

In assessing the balance of benefits and harms from screening for HIV infection in pregnant women, we highlight several areas of key uncertainties.

### Population Screened

Studies that have assessed the usefulness of risk factor assessment to guide screening were mostly performed before the CDC recommended universal counseling and voluntary prenatal HIV testing, but indicated that targeted screening missed a significant proportion of HIV-positive women. Even with universal counseling and voluntary testing policies, a significant minority of women remains untested. Studies evaluating programs to increase uptake rates in target groups such as adolescent minority women are lacking.

Currently recommended HIV counseling prior to testing and subsequent follow-up require substantial resources. More abbreviated or streamlined counseling methods (including opt-out testing policies) might encourage more providers to offer screening and patients to accept it, but could also result in less informed choices by women, and require further study. There are also insufficient data regarding the usefulness of repeat screening in the third trimester in high- or low-risk women who tested negative earlier.

### Screening Methods

Rapid serum testing of women with unknown HIV status presenting in labor appears to be an accurate and feasible method for quickly determining eligibility for urgent interventions. The effect of other sampling or testing methods (home-based sampling, urine or oral specimens, or on-site testing) on acceptance of testing and rates of patient notification of results have not been evaluated in pregnant women, but could be effective in women who receive limited or no prenatal care or who do not undergo standard office-based testing for other reasons.

### Harms from Screening

Anecdotal reports of violence, suicide, partnership dissolution, and other adverse effects from screening are concerning, but data to estimate the magnitude of these harms are limited. Pregnant women may be particularly vulnerable to these adverse effects. Good-quality studies on methods to minimize the risk of these harmful outcomes are lacking.

### Interventions

The combination of antiretroviral prophylaxis, elective cesarean section, and avoidance of breastfeeding is highly effective in reducing rates of mother-to-child transmission of HIV infection. Studies on long-term maternal and infant risks and benefits associated with different combination regimens, however, are not yet available. Further studies are needed to determine the optimal antiretroviral regimen, and whether elective cesarean section has an additive effect in women receiving HAART. The long-term effects of transient antiretroviral exposure or less-intense antiretroviral regimens during pregnancy on resistance rates and future response to therapy also need to be studied further. There are insufficient data regarding the effectiveness of counseling on rates of vertical or horizontal transmission, or on the effect that knowledge of HIV status has on future reproductive choices.

## Future Research

Studies evaluating short and long-term effects of different antiretroviral regimens, particularly in women who do not otherwise meet criteria for initiation of HAART, are being conducted and will help clarify the optimal antiretroviral regimen choice during pregnancy. Longer-term follow-up studies of women and infants who received antiretrovirals are also being conducted and remain a priority. Particular attention should be paid to long-term outcomes in women who discontinued antiretrovirals after delivery to determine whether brief exposure affects future response rates or the choice of subsequent antiretroviral regimens. Children exposed to antiretrovirals in utero should continue to be followed to help identify unexpected or emerging long-term harms from combination regimens.

Most studies of HIV-infected pregnant women have focused on benefits from reductions in mother-to-child transmission rates. Studies evaluating the effects of HIV diagnosis and counseling on future reproductive choices, high-risk behaviors, horizontal transmission rates, and other non-pregnancy-related outcomes could help to further strengthen the case for universal screening, particularly in low-risk populations.

Further studies of rapid tests and other new sampling and testing methods in office-based and outreach settings will help clarify their role in improving prenatal testing and notification rates. Studies evaluating methods to resolve barriers to testing remain a priority and include further evaluation on the impact of policy choices (such as opt-out testing or mandatory newborn screening) and different (such as streamlined or targeted) counseling methods on testing rates.