# Methods

## Literature Search and Strategy

We searched the topic of HIV in the MEDLINE® and Cochrane Library databases. Most searches were carried out from 1983 (the year that HIV was characterized) through June 30, 2004. For searches on antiretroviral therapy, electronic searches were performed from 1998, the year that highly active antiretroviral therapy (HAART) was first recommended in U.S. guidelines,^67^ and supplemented by an electronic search for systematic reviews of antiretroviral therapies from 1983. We performed a total of 13 searches covering the areas of risk factor assessment, screening tests, work-up, and interventions. Because a preliminary search found that search strategies limited by terms for pregnancy excluded relevant studies, we performed general searches on topics of interest and performed supplemental searches specifically related to pregnancy. Detailed electronic search strategies and results are presented in Appendix A. Periodic hand searching of relevant medical journals, reviews of reference lists, and peer review suggestions supplemented the electronic searches. Abstracts were not included in systematic searches, but major abstracts cited in reference lists or presented at recent conferences were included. Reviews, policy statements, and other papers with contextual value were also obtained.

## Inclusion / Exclusion Criteria

A single reader reviewed all English abstracts. Papers were selected for full review if they were about HIV infection in pregnant women, relevant to key questions, and met inclusion criteria. For all key questions, articles were limited to those that evaluated the general population of pregnant women with HIV infection. Although the population of interest was pregnant women with unsuspected HIV infection who would be identified by screening, we included studies of pregnant women with a broad spectrum of chronic HIV disease in order to get a picture of the benefits and adverse effects of screening and treatment in patients with different degrees of immune deficiency. We included studies performed in the U.S., Australia, Canada, and Western Europe in which the epidemiology and management of chronic HIV infection are similar. When important studies for a specific key question had only been performed in other countries, these were included as well. Studies of non-human subjects and those without original data were excluded. Foreign language papers were considered if they were clinical trials and an abstract was available in English. We searched for relevant systematic reviews for all key questions. Additional key question-specific inclusion criteria are listed in Appendix B.

## Data Extraction and Synthesis

We used predefined criteria from the USPSTF to assess the internal validity of included systematic reviews, trials and observational studies, which we rated as “good,” fair,” or “poor.” We also rated the applicability of each study to the population that would be identified by screening. The rating system was developed by the USPSTF and is described in detail elsewhere and summarized in Appendix C.^68^ For included trials and systematic reviews, we abstracted information about setting, patients, interventions, and outcomes. We presented full evidence tables for selected high-priority key questions, and more concise tables for other key questions. We rated the overall body of evidence for each key question using the system developed by the USPSTF.

## Size of Literature Reviewed

Investigators reviewed 5,993 abstracts identified by the searches (Appendix D). From the searches, 1,866 full-text articles were reviewed. An additional 809 non-duplicate articles identified from reference lists and experts were also reviewed.

Appendix D. Search and Selection Of Literature