# Introduction

This evidence synthesis focuses on screening for unsuspected human immunodeficiency virus (HIV) using HIV antibody (Ab) tests in pregnant women, including adolescents. The review will be used by the U.S. Preventive Services Task Force (USPSTF) to make recommendations regarding screening in pregnant women.

Since the USPSTF last published recommendations regarding HIV screening of pregnant women in 1996, there have been substantial changes in the management of pregnant women with HIV and in the rates of mother-to-child transmission. Although this report reviews the overall body of evidence regarding screening for HIV infection in pregnant women, it focuses on more recent data regarding the efficacy of combination antiretroviral regimens in prevention of mother-to-child transmission, harms associated with receipt of antiretrovirals in pregnancy, and the accuracy and acceptability of rapid testing.

## Burden of Condition / Epidemiology

Women are the fastest growing group of persons with new HIV diagnoses, with 30% of new HIV infections diagnosed in women in 2001, and the incidence rising most rapidly among young minority women.^1,^ ^2^ There are 120,000–160,000 HIV-infected women (80% of childbearing age) residing in the U.S.^3^ HIV seroprevalence among all U.S. women of childbearing age is estimated at 1.5 to 1.7 per 1000 women, but is higher in certain geographic areas.^4^–^6^ Among women in New York City, for example, the prevalence of HIV among childbearing women was estimated at 0.62% in 2000.^7^ As of 2003, approximately 3,788 perinatally infected persons were living with AIDS in the U.S., and there had been an estimated 4,961 cumulative deaths of children from perinatally acquired AIDS.^8^ An estimated 6,000–7,000 HIV-positive women give birth each year in the U.S.^5^ The number of cases of perinatally transmitted HIV, however, has declined sharply in the U.S. since the early 1990's.^5,^ ^9^ In 1994, for example, 213 cases of perinatally transmitted HIV were reported to the Centers for Disease Control and Prevention (CDC) by 25 states with confidential name-based reporting, compared to 26 cases in 2002.^10^ The CDC estimates that 280–370 HIV-infected infants were born in the United States each year between 1999 and 2001.^11^ In 2000, 40% of HIV-infected infants were born to mothers not known to have HIV infection before delivery.^12^

## Healthcare Interventions

There is no effective vaccine to prevent HIV infection and no cure for chronic infection. In HIV-infected pregnant women, a major goal of interventions is to reduce the risk of mother-to-child transmission. Other important goals are to improve clinical outcomes in the mother, facilitate early identification of infected newborns, allow women to make informed future reproductive choices, and prevent horizontal transmission through counseling on risky behaviors. Interventions for HIV-infected pregnant women include antiretroviral therapy, avoidance of breastfeeding, specific labor and delivery management techniques such as cesarean section before labor and before rupture of membranes (elective cesarean section), prophylaxis for opportunistic infections, immunizations, counseling to reduce high-risk behaviors, and regular monitoring and follow-up. In the U.S., receipt of combination antiretrovirals in conjunction with elective cesarean section in selected women and avoidance of breastfeeding is the standard of care to reduce mother-to-child transmission of HIV.^13,^ ^14^

Management of HIV infection in pregnancy is a rapidly evolving area. Detailed and regularly updated U.S. guidelines regarding specifically recommended antiretroviral regimens in pregnancy,^14^ chemoprophylaxis for opportunistic infections and immunizations,^15,^ ^16^ counseling methods,^17,^ ^18^ and labor management techniques^14,^ ^19^ are available. Guidelines recommending avoidance of breastfeeding by HIV-infected women remain unchanged.^18,^ ^20^ Current guidelines regarding the specific choice of initial antiretroviral therapy are based on a combination of results from clinical trials and observational studies, and special considerations such as convenience, potential risk to the fetus, side effect profile, and potential for drug interactions and the development of resistance.^14,^ ^21^

## Natural History

Mother-to-child transmission of HIV infection can occur during pregnancy (antepartum), during labor and delivery (intrapartum), and following delivery (postnatal). In the absence of breastfeeding, intrauterine transmission is thought to account for 25% to 40% of vertically infected infants, with the remainder infected during labor and delivery.^18^ A high proportion of intrauterine transmission is thought to occur shortly before delivery.^22^ Following delivery, HIV virus is present in and transmitted through breast milk.^23^ Breastfeeding is thought to be the only important mode for postnatal transmission.^11,^ ^24^ In resource-poor settings in which women breastfeed for prolonged periods, postnatal transmission accounts for about 44% of infant cases.^25^ A recent large (N=4,085) meta-analysis^26^ of individual patient data from clinical trials in resource-poor settings found that the risk of late (after 4 weeks) postnatal transmission through breastfeeding was relatively constant at 8.9 transmissions/100 child-years of breastfeeding and higher than reported in a previous meta-analyses of observational studies,^27,^ ^28^ though definitions of late transmission varied.

Risk factors for peripartum transmission include high viral load,^29^–^37^ immunologically or clinically advanced disease in the mother,^29,^ ^38,^ ^39^, prolonged rupture of membranes,^30,^ ^34,^ ^37,^ ^38,^ ^40^–^43^ maternal infection with other sexually transmitted diseases,^44^ and procedures or events (such as abruptio placentae, fetal scalp electrode use, episiotomy, and second-degree or greater perineal laceration) associated with an increased probability of bodily fluid contact between mother and infant.^31,^ ^44,^ ^45^ Illicit drug abuse was associated with an increased risk of maternal-to-child HIV transmission in most^30,^ ^34,^ ^37,^ ^38,^ ^40^–^42,^ ^46^ but not all^30,^ ^36,^ ^38,^ ^47,^ ^48^ studies. Smoking,^30,^ ^34,^ ^41,^ ^43^ co-infection with hepatitis C, ^34,^ ^40^ increased number of sexual partners or frequency of unprotected intercourse,^46^ and the presence of maternal antiretroviral resistance mutations^49,^ ^50^ have also been associated with an increased risk of mother-to-child transmission.

Risk factors for clinical progression (in particular high viral load and low CD4 count) appear to be similar for HIV-infected pregnant and non-pregnant women. In developed countries, pregnancy does not appear to be an important independent predictor of clinical progression in chronically infected HIV-positive women.^51,^ ^52^ The clinical implications of significant viral load increases that have been observed following delivery in women who either received or did not receive antiretroviral therapy are unclear.^53^–^55^

## Prior Recommendations

The USPSTF published guidelines for HIV screening in 1996.^56^ At that time, the USPSTF recommended that clinicians should screen all high-risk pregnant women, including all women who live in states, counties, or cities with increased prevalence of HIV (“A” recommendation). Increased prevalence of HIV was defined as a seroprevalence in newborns of greater than or equal to 0.1%. The USPSTF found insufficient evidence to recommend for or against universal screening in low-risk pregnant women in low-prevalence areas.

The American Academy of Pediatrics and theAmerican College of Obstetricians and Gynecologists,^57^ the Institute of Medicine,^58^ and the Centers for Disease Control and Prevention^18^ recommend universal counseling and voluntary testing for HIV in all pregnant women as part of routine prenatal care (Table 1).

Table 1 U.S. Guidelines For HIV Counseling And Testing In Pregnant Women

Organization | Year | Who to screen | Reference
US Preventive Services Task Force | 1996 | All high-risk pregnant women, including women living in states, counties or cities with a newborn prevalence of HIV infection >=0.1%. | USPSTF, 1996^56^
Centers for Disease Control and Prevention | 2001 | Universal screening of pregnant women during prenatal care or at time of presentation to labor & delivery if not already done with maternal right to refuse testing | CDC, 2001^18^
American Academy of Pediatrics | 1995 | Universal screening of pregnant women with maternal right to refuse testing | American Academy of Pediatrics, Provisional Committee on Pediatric AIDS, 1995^73^
American College of Obstetricians and Gynecologists | 1999 | Universal screening of pregnant women with maternal right to refuse testing | Joint Statement of AAP and ACOG, 1999^57^
Institute of Medicine | 1999 | Universal screening of pregnant women with maternal right to refuse testing | Institute of Medicine, 1999^58^

## Scope of Evidence Synthesis

The analytic framework in Figure 1 indicates the strategy we used to evaluate screening for HIV-1 infection in pregnant women. The key questions (Figure 2), which guided our literature review, were developed in conjunction with liaisons from the USPSTF and external expert reviewers.

Figure 1. Screening For Human Immunodeficiency Virus (HIV): Analytic Framework For Pregnant Women

Figure 2. Screening for Human Immunodeficiency Virus (HIV): Key Questions for Pregnant Women Analytic Framework

The analytic framework shows the target populations, interventions, and intermediate and health outcome measures we examined. We included all pregnant women regardless of age. Our review considered the standard screening strategy for HIV-1 infection an office-based venipuncture with a repeatedly reactive serum anti-HIV enzyme-linked immunosorbent assay (EIA), followed by confirmatory Western blot or immunofluorescent assay for positive tests. The other major screening method that we considered was the use of rapid testing in women with unknown HIV status presenting to labor and delivery units. We also considered data on the use of home-based collection methods and tests using non-invasive samples such as saliva or urine in pregnant women. Viral load and CD4+ cell count testing was considered the standard work-up to determine the stage of infection in seropositive patients.

For treatment of HIV infection in pregnant women, we evaluated recommended antiretroviral therapies, prophylaxis for opportunistic infection, immunizations, avoidance of breastfeeding, labor management techniques such as elective cesarean section in women with viral loads >1,000 copies/ml, counseling to reduce risky behaviors, and routine monitoring and follow-up. We did not include interventions not shown to be effective or not recommended in current guidelines for antiretroviral-naïve pregnant women in the U.S., such as hydroxyurea,^14^ HIV immune globulin,^59^ vitamin supplementation,^60^ routine resistance testing,^61^ and specific antiretroviral agents (such as efavirenz in the first trimester or the oral liquid formulation of amprenavir) or combinations (such as stavudine plus didanosine)^14,^ ^21^ that are no longer recommended. The major clinical outcome of interest in this review was mother-to-child transmission of HIV. We also reviewed data regarding the risk of clinical progression and mortality in HIV-positive women identified during pregnancy. Adverse outcomes of interventions in both mothers and infants were reviewed, emphasizing severe or intolerable events. We were also particularly interested in evidence regarding long-term maternal and child risks from antiretroviral therapy from exposure during pregnancy. Although antiretroviral therapy is associated with significant short-term side effects, many patients can be switched to effective alternative regimens, and intolerable or serious side effects are incorporated into intention-to-treat analyses of clinical outcomes.^62^ Intermediate outcomes were loss of detectable viremia, improvement in CD4 counts, and changes in risky behaviors. We also reviewed harms from screening, work-up and treatment. Although the potential for the development of antiretroviral resistance is an important consideration in deciding which antiretroviral regimen to use during pregnancy, we primarily focused on reviewing the effects of resistance on long-term clinical outcomes.^63^–^66^