# Appendix F. Reviewers

Content Experts | Doug Campos-Outcalt, MD
| Associate Head, Family & Community Medicine & Preventive Medicine; Clinical Professor, Family & Community Medicine
| University of Arizona College of Medicine
| Ken Freedberg, MD
| Massachusetts General Hospital
| Ron Goldschmidt, MD
| San Francisco General Hospital
| University of California, San Francisco
| Wm. Christopher Mathews, MD, MSPH
| Director, University of California-San Diego Owen Clinic
| Professor of Clinical Medicine
| University of California-San Diego Medical Center
| James M. Oleske, MD, MPH
| François-Xavier Bagnoud Professor of Pediatrics
| Director, Division of Pulmonary, Allergy, Immunology & Infectious Diseases
| Department of Pediatrics
| New Jersey Medical School
| Douglas K. Owens, MD, MS
| Associate Professor of Medicine and of Health Research and Policy
| Acting Director, Center for Primary Care and Outcomes Research and Center for Health Policy
| Stanford University
| Jeffrey F. Peipert, MD, MPH
| Women & Infants' Hospital
| John P. Phair, MD
| Northwestern University
| Henry Sacks, MD, PhD
| Mount Sinai School of Medicine
| Infectious Diseases
| Evan Wood, PhD
| Department of Health Care and Epidemiology, University of British Columbia
| BC Centre for Excellence in HIV/AIDS, St Paul's Hospital
US Preventive Services Task Force | Janet Allen, PhD, RN
| Dean and Professor
| School of Nursing
| University of Maryland, Baltimore
Federal Agencies | Bernard M. Branson, MD
| Centers for Disease Control and Prevention (CDC)
| John T. Brooks, MD
| Centers for Disease Control and Prevention (CDC)
| Vicki Cargill, MD, MSCE
| NIH - Office of AIDS Research
| Sam Dooley
| Centers for Disease Control and Prevention (CDC)
| Mary Glenn Fowler, MD (with input from Drs. John Anderson and Kim Miller)
| Centers for Disease Control and Prevention (CDC)
| Epidemiology Branch
| National Center for HIV, STD and TB Prevention (NCHSTP)
| Division of HIV/AIDS (DHAP)
| Kathleen Gallagher
| Centers for Disease Control and Prevention (CDC)
| Catherine Godfrey, MD
| Division of AIDS
| National Institute of Allergy and Infectious Diseases (NIAID)
| National Institutes of Health (NIH)
| Scott Holmberg, MD, MPH
| Centers for Disease Control and Prevention (CDC)
| Shirley Jankelovich, MD
| Division of AIDS
| National Institute of Allergy and Infectious Diseases (NIAID)
| National Institutes of Health (NIH)
| Leila C. Kahwati, MD, MPH
| Veterans Health Administration National Center for Health Promotion and Disease Prevention
| Laurie Kamimoto
| Centers for Disease Control and Prevention (CDC)
| National Center for HIV, STD and TB Prevention (NCHSTP)
| Division of HIV/AIDS (DHAP)
| HIV Incidence and Case Surveillance Branch (HICSB)
| Linda Kinsinger, MD, MPH
| Veterans Health Administration National Center for Health Promotion and Disease Prevention
| Matthew McKenna
| Centers for Disease Control and Prevention (CDC)
| National Center for HIV, STD and TB Prevention (NCHSTP)
| Division of HIV/AIDS (DHAP)
| HIV Incidence and Case Surveillance Branch (HICSB)
| Lynne M. Mofenson, MD
| Pediatric, Adolescent, and Maternal AIDS (PAMA) Branch
| Center for Research for Mothers and Children (CRMC)
| National Institute of Child and Human Development (NICHD)
| National Institutes of Health (NIH)
| Jennifer S. Read, MD, MS, MPH, DTM&H
| Pediatric, Adolescent, and Maternal AIDS (PAMA) Branch
| National Institute of Child and Human Development (NICHD)
| National Institutes of Health (NIH)
| Monica S. Ruiz, PhD, MPH
| Division of AIDS
| National Institute of Allergy and Infectious Diseases (NIAID)
| National Institutes of Health (NIH)