# Appendix E. Statistical Methods Used For Outcomes Table (Table 16)

## Calculation of numbers needed to screen (NNS) and numbers needed to treat(NNT)

Calculations of NNS and NNT were based on estimates from different sources in the literature (Table 16). The indicated range of estimates and variation associated with estimates were incorporated in the calculations and reflected by the ranges in the calculated NNS and NNT. Variation associated with the estimates was estimated using Monte Carlo simulations. The distributions of the estimates used in the simulations were either the underlying distribution on which the calculation of 95% confidence interval (CI) was based, or one that best approximated the point estimate and CI. For example, if the estimate was a rate or proportion, the logit of the rate or proportion was sampled assuming an approximately normal distribution, and then transformed back to its original scale. For relative risk, we assumed that the log of relative risk was approximately normally distributed. The point estimates and 95% CI of NNS and NNT were based on 1,000,000 simulations.