# Evidence Tables

Evidence Table 1. Published Head-to-Head Trials of Haart Regimens in Antiretroviral Naive or Near-Naive Patients

Author, year | Type of study/ Setting | Aims | Study duration | Eligibility criteria | Exclusion criteria | Screened/ Eligible/ Enrolled population | Withdrawals or loss to follow-up (%) analyzed | Demographics / Baseline disease | Outcomes assessed | Interventions | Virologic response | CD4 count response | Clinical outcomes | Adverse events | Funding source and role | Internal validity rating | Relevance to screening | Comments
Carr, 2000^466^ | RCT Multicenter | Compare three different three-drug regimens containing IDV | 52 weeks | Documented HIV infection, Age >18 years, antiretroviral naïve, CD4 <500 cells/mm^3^ or viral load >30,000 copies/ml, no active AIDS-related condition or major organ failure, standard opportunistic infection prophylaxis, negative pregnancy test in women of child-bearing age | Current chemotherapy, radiotherapy, or immune therapy, and no ongoing alcohol or substance abuse | Not reported | 106 analyzed | Mean age: 38 | Primary outcomes: Time-weighted mean change from baseline viral load at week 52, proportion of patients with viral load <50 copies/ml at week 52, and the proportion of patients with drug-related toxicity requiring dose modification or drug cessation | A: AZT 250 mg bid + 3TC 150 mg bid + IDV 800 mg tid | A vs. B vs. C | A vs. B vs. C | Quality of life improved in all groups, no differences between interventions, using unspecified scale | A vs. B vs. C | Commonwealth Department of Health and Aged Care Services, Bristol-Myers Squibb, GlaxoWellcome, Merck Sharp and Dohme, Australia, role of funder not reported | FAIR | II. Number screened and eligible not reported, clinical stage not reported | Level of adherence the most important predictor of virologic outcome at 52 weeks, rather than the specific regimen.
OzCombo1 | Australia and New Zealand | | | | | 109 | 32/106 (30%) withdrew | Female gender: 93% | Secondary endpoints: Overall safety, adverse events, adherence, CD4 counts, delayed type hypersensitivity response, and quality of life | B: d4T 40 mg bid + 3TC 150 mg bid + IDV 800 mg tid | Percent with HIV-1 RNA level <50 copies/ml at week 52: /35) 66% vs. /34) 59% vs. /37) 48% | Mean increase in CD4 count at week 52: 275 vs. 237 vs. 176 cells/mm^3^ | | Did not complete 52 weeks of assigned treatment: 10/35 (29%) vs. 6/34 (18%) vs. 16/37 (37%) | | Open-label
| | | | | | 106 | | Race: Not reported | | C: d4T 40 mg bid + ddI 200 mg bid + IDV 800 mg tid | | | | Did not complete 52 weeks due to adverse events: 8/35 vs. 4/34 vs. 9/37
| | | | | | | | Mean CD4 count: 285 cells/mm^3^
| | | | | | | | Mean viral load: 5.07 log_10_ copies/ml
Cohen Stuart, 1999^467^ | RCT Multicenter | Compare 3-drug regimens with SQV soft gel capsules vs. IDV | 24 weeks | >18 years old, antiretroviral-naïve except AZT; viral load ≥10,000 copies/ml or CD4 counts <500 cells/mm^3^or CDC stage B or C | Significant liver test, renal test, or hematologic test abnormalities; requiring acute therapy for opportunistic infection or systematic antineoplastic chemotherapy or radiotherapy, malabsorption or inadequate oral intake; chronic diarrhea; pregnant or breast-feeding; participant in another study within 30 days | Not reported | 70 analyzed | Age: Mean 38 years | Primary outcomes: Viral load <400 copies/ml at 24 weeks, viral load <50 copies/ml at 24 weeks | A: IDV 800mg tid + AZT 200 mg tid + 3TC 150 mg bid | A vs. B | A vs. B | A vs. B | A vs. B | Funding by Hoffman-La Roche Netherlands, role of funder not reported | FAIR | II. Number screened and eligible not reported, only CDC stage B or C included
CHEESE | The Netherlands | | | | | Not reported | 10/70 (14%) discontinued prior to week 24 | Gender: 38% female | Secondary outcomes: CD4 cell counts, AIDS-defining events, adverse events | B: SQV-SQC 1200 mg tid + AZT 200 mg tid + 3TC 150 mg bid | Percent with HIV-1 RNA level of <400 copies/ml at 24 weeks: 83% vs. 86% (ITT, p=0.74), 90% vs. 96% (on-treatment, p=0.57) | Mean CD4 cell count increase at week 24: 162 vs. 89 cells/mm^3^ (p=0.01, repeated-measures analysis) | Death: 1/35 vs. 2/35 | Withdrawal due to adverse events: 1/35 (3%) vs. 4/35 (11%) (NS) | | Open-label
| | | | | | 70 | | Non-white race: 10% | Assessed every 4 weeks | | Percent with HIV-1 RNA level of <50 copies/ml at 24 weeks: 26/35 (74%) vs. 25/35 (71%) (ITT, p=0.78), 88% vs. 85% (on-treatment, p=0.73) | | New AIDS-defining events: 3/35 vs. 5/35 (NS) | Nephrolithiasis (moderate or severe): 0% vs. 2/35 (6%) (NS)
| | | | | | | | Viral load: Median 4.99 log_10_ copies/ml | | | | | | Diarrhea (moderate or severe): 5/35 (14%) vs. 1/35 (3%) (NS)
| | | | | | | | CD4 count: Mean 305 cells/mm^3^ | | | | | | Nausea: 5/35 (14%) vs. 5/35 (14%) (NS)
| | | | | | | | Prior AZT: 4% | | | | | | Gastritis: 0% vs. 1/35 (3%) (NS)
| | | | | | | | Prior AIDS-defining illness: 24% | | | | | | Hematemesis: 1/35 (3%) vs. 0%
| | | | | | | | | | | | | | Urine bladder polyp: 0% vs. 1/35 (3%)
| | | | | | | | | | | | | | Grade 4 anemia: 0% vs. 1/35 (3%)
Eron, 2000^469^ | RCT Multicenter | Compare two different 3-drug regimens with a protease inhibitor | 48 weeks | >16 years old; laboratory-documented HIV infection; CD4 count ≥200 cells/mm^3^; viral load ≥10,000 copies/ml; ≤28 days prior cumulative treatment with AZT, ddI, d4T, or ddC; no prior 3TC or PI; acceptable laboratory values | AIDS-defining illness requiring treatment within 30 days, requirement for biologic response modifiers, systemic corticosteroids, or investigational agents within 30 days, moderate or severe peripheral neuropathy, diarrhea, or severe malabsorption, inability to tolerate oral medication, history of acute or chronic pancreatitis, hepatitis, or nephrolithiasis, or pregnancy or nursing | Not reported | 205 analyzed | Age: Not reported | Primary outcomes: Viral load <500 copies/ml and <50 copies/ml at 48 weeks | A: d4T 40 mg bid + ddI 200 mg bid + IDV 800 mg tid | A vs. B | A vs. B | A vs. B | A vs. B | Funding by Bristol-Myers Squibb Company, role of funder not reported | FAIR | II. Number screened and eligible not reported, CDC stage not reported
START II | USA | | | | | Not reported | 83/205 (41%) discontinued prior to week 48 | Gender: 15% female | Secondary outcomes: Time to rebound of HIV-1 RNA level (days from initial HIV-1 RNA <500 copies/ml to >500 copies/ml), CD4 counts | B: AZT 200 mg tid or 300 mg bid + 3TC 150 mg bid + IDV 800 mg q8h | Percent with HIV-1 RNA level of <500 copies/ml at 48 weeks: 50% vs. 41% (ITT, p=0.166), 83% vs. 79% (on-treatment, p>0.2) | Median CD4 cell count increase at week 48: 214 vs. 142 cells/mm^3^ (p=0.026) | Death: 2/102 (2%) vs. 0/103 (0%) | Withdrawal due to adverse events: 16/102 (16%) vs. 16/103 (16%) | | Open-label
| | | | | | 205 | | Non-white race: 39% | | | Percent with HIV-1 RNA level of <50 copies/ml at 48 weeks: 41% vs. 35% (ITT, p>0.2) | Median time-weighted average minus baseline increase in CD4 cell count at week 48: 150 vs. 106 cells/mm^3^ (p=0.001) | New CDC class C AIDS defining event: 1/102 (1%) vs. 1/103 (1%) | Serious adverse events (requiring hospitalization or considered life-threatening by investigator): 8/102 (8%) vs. 8/103 (8%)
| | | | | | | | Viral load: Median 4.50 log_10_ copies/ml | | | Probability of viral load relapse by week 48: 24% vs. 36% | | | Nausea (grade 3 or 4): 2% vs. 2%
| | | | | | | | CD4 count: Median 422 cells/mm^3^ | | | | | | Rash (grade 3 or 4): 2% vs. 0%
| | | | | | | | | | | | | | Taste perversion (grade 3 or 4): 0% vs. 1%
| | | | | | | | | | | | | | Fever (grade 3 or 4): 2% vs. 2%
| | | | | | | | | | | | | | Paresthesia (grade 3 or 4): 0% vs. 0%
| | | | | | | | | | | | | | Sinusitis (grade 3 or 4): 0% vs. 0%
| | | | | | | | | | | | | | Total bilirubin (grade 3 or 4): 16% vs. 8%
| | | | | | | | | | | | | | Aspartate Transaminase (grade 3 or 4): 7% vs. 5%
| | | | | | | | | | | | | | Alanine Transaminase (grade 3 or 4): 8% vs. 5%
| | | | | | | | | | | | | | Amylase (grade 3 or 4): 8% vs. 2%
| | | | | | | | | | | | | | Gammaglutamyl Transpeptidase (grade 3 or 4): 5% vs. 2%
| | | | | | | | | | | | | | Triglycerides (nonfasting, grade 3 or 4): 3% vs. 4%
Eron, 2004^468^ | RCT Multicenter | Compare once-daily to twice-daily HAART regimen | 48 weeks | Viral load >50 copies/ml, antiretroviral naïve, >12 years old | Recent opportunistic infection, significant abnormal liver tests, pregnant or breastfeeding | 51 screened | 4/38 (11%) withdrew | Mean age: 42 vs. 35 years | Primary outcome: Viral load <50 copies/ml at 24 weeks and time to loss of virological response | A: Lopinavir 800 mg/RTV 200 mg qD + d4T 40 mg bid + 3TC 150 mg bid | A vs. B | A vs. B | No deaths or CDC stage C events | Withdrawal due to adverse events: 1/19 (5%) vs. 1/19 (5%) | Abbott Laboratories, role not reported | FAIR | II. Clinical stage not reported
| USA | | | | | 38 eligible | 38 analyzed | Female gender: 32% | Secondary outcomes: Viral load <50 copies/ml at 48 weeks and changes in CD4 count | B: Lopinavir 400 mg/RTV 100 mg bid + d4T 40 mg bid + 3TC 150 mg bid | Percent with viral load <50 copies/ml at week 48: 14/19 (74%) vs. 15/19 (79%) (ITT, p=0.70) | Mean CD4 cell count increase at week 48: 235 vs. 248 cells/mm^3^ | | At least moderate adverse event possibly related to lopinavir/RTV: 3/19 vs. 5/19 | | Open-label
| | | | | | 38 enrolled | | Nonwhite race: 5/19 vs. 6/19
| | | | | | | | Mean CD4 count: 265 vs. 252 cells/mm^3^
| | | | | | | | Mean viral load: 4.6 vs. 4.7 log_10_ copies/ml
Fischl, 2003^470^ | RCT Multicenter | Compare 2 different 4-drug regimens to a 3-drug regimen | 2.1 years | CD4 count <200 cells/mm^3^ or viral load >80,000 copies/ml, no or limited prior antiretorival therapy | Significant abnormal lab values including hematologic and liver tests, pregnant or breast-feeding | Not reported | 110/504 (22%) discontinued | Mean age: 38 years | Primary outcome: Time to virologic failure (increase in viral load greater than baseline or 1.0 log greater than nadir, viral load >200 copies/ml at week 24, or virologic relapse | A: AZT 300 mg/3TC 150 mg bid + IDV 800 tid | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | Withdrawal (overall): 28/168 (17%) vs. 28/173 (12%) vs. 19/176 (11%) | AIDS clinical trials group, NIAID, NIH provided funding; Merck, DuPont, Pharmaceuticals, Agouron Pharmaceuticals, GlaxoSmithKline, Bristol-Myers Squibb provided medications | FAIR | II. Number screened and eligible not reported, clinical stage not reported
ACTG 388 | United States and Italy | | | | | Not reported | 516 analyzed | Female gender: 19% | Secondary outcomes: changes in CD4 counts, proportion of patients with viral load <200 copies/ml or 50 copies/ml, time to treatment failure (includes clinical outcomes) | B: AZT 300 mg/3TC 150 mg bid + IDV 1000 mg tid + EFV 600 mg qD | Virologic failure: 52/168 (31%) vs. 39/173 (23%) vs. 81/175 (46%) (ITT, p=0.04 for B vs. A, p=0.06 for C vs. A) | Mean CD4 cell count increase at week 96: 250 vs. 265 vs. 257 cells/mm^3^ (NS) | Deaths: 13/517 (2.5%) | Withdrawal (adverse events): not reported | | Open-label
| | | | | | 517 enrolled | | Non-white race: 52% | | C: AZT 300 mg/3TC 150 mg bid + IDV 1000 bid + NFV 1250 bid | Percent with viral load <200 copies/ml or <50 copies/ml at week 24 or later not reported | | AIDS-defining cases: 59/517 (11%); 5.7/100 person-years | Grade 3 or 4 adverse events: 35/168 (21%) vs. 41/173 (24%) vs. 50/175 (28%) (p=0.49 for A vs. B and p=0.12 for A vs. C)
| | | | | | | | Mean CD4 count: 161 cells/mm^3^ | | | | | AIDS or death: 6.9/100 person-years | Grade 3 or 4 lab abnormalities: 57/168 (34%) vs. 58/173 (34%) vs. 63/176 (36%) (NS)
| | | | | | | | Mean viral load: 5.42 copies/ml | | | | | | Neprholithiasis more frequent in A (p<0.01)
| | | | | | | | 90% naïve | | | | | | Grade 3 or 4 bilirubin elevation more frequent in A and C (p<0.001)
| | | | | | | | | | | | | | Neutropenia more common in C (p=0.05)
French, 2002^471^ | RCT Multicenter | Compare three different three-drug regimens containing NVP | 52 weeks | Antiretroviral-naïve, >18 years old, CD4 count >50 cells/mm^3^, negative pregnancy test if applicable, no active or ongoing opportunistic infection, no current chemotherapy, radiotherapy, or immune therapy, and no ongoing alcohol or substance abuse | Liver function tests greater than five times the upper limit of normal | Not reported | 5 didn't receive study drug | Age: Mean 37 years | Primary outcomes: Time weighted mean change from baseline in plasma HIV RNA at week 52 and the proportion of patients with viral load <500 copies/ml and <50 copies/ml | A: AZT 250 mg bid + 3TC 150 mg bid + NVP 200 mg bid | A vs. B vs. C | A vs. B vs. C | No deaths | A vs. B vs. C | Supported by the Commonwealth Department of Health and Aged Care, and multiple pharmaceutical companies, role not clear | FAIR | II. Number screened and eligible not reported
Ozcombo 2 | Australia | | | | | Not reported | 17/70 (26%) discontinued | Gender: 9% female | Secondary outcomes: Changes in CD4 counts and quality of life scores | B: d4T 40 mg bid + 3TC 150 mg bid + NVP 200 mg bid | Percent with HIV-1 RNA level of <500 copies/ml at 52 weeks: 74% vs. 71% vs. 87% (ITT, p=0.41) | Mean increase in CD4 count: 172 vs. 201 vs. 190 cells/mm^3^ (NS) | No AIDS-related clinical progression | Withdrawal due to adverse events: 15% vs. 18% vs. 13% | | Open-label
| | | | | | 70 | 65 analyzed | Non-white race: Not reported | | C: d4T 40 mg bid + ddI 200 mg bid + NVP 200 mg bid | Percent with HIV-1 RNA level of <50 copies/ml at 52 weeks: 73% vs. 68% vs. 80% (ITT, p=0.41) | | | Withdrawal due to peripheral neuropathy: 0% vs. 14% vs. 9%
| | | | | | | | Prior AIDS: 9% | | | | | | Grade 3 or 4 adverse events: 20% vs. 36% vs. 30%
| | | | | | | | Viral load: Mean 4.63 log_10_ copies/ml | | | | | | Grade 3 or 4 drug-related adverse events: 20% vs. 23% vs. 22%
| | | | | | | | Mean CD4 count: 399 cells/mm^3^
Gallant, 2004^472^ | RCT Multicenter | Compare tenofovir disoproxil fumarate (DF) with d4T | 144 weeks | Antiretroviral-naïve, viral load >5,000 copies/ml | Significant abnormal lab values including hematologic, hepatic, and renal tests | 753 screened | 2 patients didn't receive study drug | Mean age: 36 years | Primary outcome: Viral load <400 copies/ml at week 48 | A: tenofovir DF 300 mg qD + 3TC 150 mg bid + EFV 600 mg qD | A vs. B | A vs. B | A vs. B | A vs. B | Supported entirely by Gilead Sciences Inc, Foster City, CA | GOOD | II. Clinical stage not reported
903 Study | U.S.A., South America, and Europe | | | | | 658 eligible | 600 analyzed | Gender: 26% female | Seconday outcomes: Viral load <50 copies/ml and change in CD4 cell count at weeks 48, 96, and 144 | B: d4T 40 mg bid + 3TC 150 mg bid + EFV 600 mg qD | Percent with HIV-1 RNA level of <400 copies/ml at 48 weeks: 79.9% vs. 84.1% (ITT and switch=failure, NS) | Mean increase in CD4 count at week 144: 263 vs. 283 cells/mm^3^ | Deaths: 5/299 (2%) vs. 6/301 (2%) | Withdrawal due to adverse event or intercurrent illnes: 24/299 (8%) vs. 41/301 (14%)
| | | | | | 602 enrolled | 182/600 (30%) discontinued drug regimen | Non-white race: 36% | | | Percent with HIV-1 RNA level of <50 copies/ml at 48 weeks: 763% vs. 79.7% (ITT and switch=failure, NS) | | Category C AIDS-defining conditions: 11/299 vs. 9/301 (p=0.40) | Any grade 3 or 4 adverse event: 27% vs. 25%
| | | | | | | | Viral load: Mean 4.91 log_10_ copies/ml | | | Percent with HIV-1 RNA level of <400 copies/ml at 144 weeks: 70.6% vs. 64.1% (ITT and switch=failure, NS) | | | Any grade 3 or 4 laboratory abnormality: 36% vs. 42%
| | | | | | | | Mean CD4 count: 276 vs. 283 cells/mm^3^ | | | Percent with HIV-1 RNA level of <50 copies/ml at 144 weeks: 67.9% vs. 62.5% (ITT and switch=failure, NS) | | | Initiated lipid-lowering therapy: 5% vs. 16% (p<0.001)
| | | | | | | | | | | | | | Neuropathy: 3% vs. 10% (p<0.001)
| | | | | | | | | | | | | | Lipodystrophy: 3% vs. 19%
Garcia, 2000^473^ | RCT Multicenter | Compare twice-daily d4T plus once- or twice-daily ddI + NVP | 12 months | Antiretroviral-naïve, >18 years old, chronic HIV Infection, CD4 count >500 cells/mm^3^, viral load >5,000 copies/ml | Pregnancy, breast-feeding, active substance abuse; significant hematologic, liver test, or kidney test abnormalities, or Karnofsky score <90 | Not reported | 5 patients didn't receive study drug | Age: Not reported | Primary outcomes: Viral load <200 copies/ml at 12 months and safety | A: d4T 40 mg bid + ddI 150–200 mg bid + NVP 200 mg bid | A vs. B | A vs. B | No deaths | A vs. B | Supported by grants, otherwise funding source and role not clear | FAIR | II. Number screened and eligible not reported, CDC stage not reported
Spanish Scan Study | Spain | | | | | Not reported | 89 analyzed | Gender: 47% female | Secondary outcomes: Viral load <5 copies/ml at 12 months, time to viral rebound in patients with viral loads that decreased to <200 copies/ml, CD4 cell response, and disease progression and survival | B: d4T 40 mg bid + ddI 300–400 mg qD + NVP 400 mg qD | Percent with HIV-1 RNA level of <200 copies/ml at 12 months: 73% vs. 68% (ITT), 85% vs. 79% (on-treatment) | Mean increase in CD4 count: 132 vs. 154 cells/mm^3^ (ITT, p=0.7) | No AIDS-related clinical events | Withdrawal due to adverse event: 3/45 (7%) vs. 4/44 (9%) | | Open-label
| | | | | | 94 | 19/89 (21%) discontinued study | Non-white race: Not reported | Assessed at baseline and at 1, 2, 4, 6, 9, and 12 months | | Percent with HIV-1 RNA level of <5 copies/ml at 12 months: 40% vs. 45% (ITT), 46% vs. 53% (on-treatment) | | | Any adverse event: 16% vs. 20%
| | | | | | | | Viral load: Mean 4.38 log_10_ copies/ml | | | Probability of treatment failure: HR 1.62, 95% CI 0.54–4.8 | | | Skin rash/fever: 9% vs. 9%
| | | | | | | | CD4 count: Mean 690 cells/mm^3^ | | | | | | Pancreatitis: 0% vs. 2%
| | | | | | | | | | | | | | Lipodystrophy: 0% vs. 2%
| | | | | | | | | | | | | | Digestive intolerance: 2% vs. 2%
| | | | | | | | | | | | | | Hepatitis: 4% vs. 0%
| | | | | | | | | | | | | | Jaundice: 0% vs. 2%
| | | | | | | | | | | | | | Polyneuropathy: 0% vs. 2%
Gathe, 2004^475^ | RCT Multicenter | Compare fosamprenavir/RTV to NFV in combination with abacavir and 3TC | 48 weeks | Antiretroviral-naïve, viral load ≥1,000 copies/ml | Significant medical conditions that could compromise safety or interfere with drug absorption, or protocol-specific laboratory abnormalities | Not reported | 649 analyzed | Age: 36 years | Primary outcome: Proportion of patients with viral load <400 copies/ml at 48 weeks | A: Fosamprenavir 1400 mg/RTV 200 mg bid + abacavir 300 mg bid + 3TC 150 bid | A vs. B | A vs. B | A vs. B | A vs. B | Funded by GlaxoSmithKline Research and Development, role of funder not reported | FAIR | II. High proportion of CDC stage C, number screened and eligible not reported
SOLO | North America, Europe, South Africa, and Australia | | | | | Not reported | 124/649 (19%) withdrew prior to 48 weeks | Gender: 27% female | Secondary outcomes: Proportion of patients with viral load <50 copies/ml at 48 weeks, changes from baseline viral load and CD4 count | B: NFV 1250 bid + abacavir 300 bid + 3TC 150 bid | Percent with HIV-1 RNA level of <400 copies/ml at 48 weeks: 68% vs. 65% (ITT missing=failure, NS) | Mean increase in CD4 count: 203 vs. 207 cells/mm^3^ | Deaths: None reported | Withdrawals due to adverse events: 28/322 (9%) vs. 16/327 (5%) | | Open-label
| | | | | | 649 | | Race: 47% non-white | | | Percent with HIV-1 RNA level of <50 copies/ml at 48 weeks: 56% vs. 52% (ITT missing=failure, NS) | | AIDS-defining diseases: None reported | Grade 2–4 adverse event: 41% vs. 39%
| | | | | | | | Viral load: median 4.8 log_10_ copies/ml | | | | | | Grade 3 or 4 lab abnormalities: No significant differences between interventions
| | | | | | | | Median CD4 count: 166 vs. 177 cells/mm^3^ | | | | | | Diarrhea: 16% vs. 9% (p=0.008)
| | | | | | | | CDC stage C: 22% | | | | | | Discontinued abacavir due to suspected abacavir hypersensitivity: 8% vs. 8%
| | | | | | | | Hepatitic C positive: 18%
Gathe, 2002^474^ | RCT Multicenter | Compare enteric-coated ddl in a 3-drug regimen with standard 3-drug regimen | 48 weeks | >12 years old, <4 weeks nucleoside analog therapy and <1 week protease inhibitor, viral load ≥2,000 copies/ml | Recent intractable diarrhea or hepatitis, history of pancreatitis, current peripheral neuropathy, additional inclusion and exclusion criteria ‘typical and appropriate for studies of this type’ | Not reported | 511 analyzed | Age: Not reported | Primary outcome: Proportion of patients with viral load <400 copies/ml at 48 weeks | A: Enteric-coated ddl 400 mg po qD + d4T 40 mg bid + NFV 750 mg tid | A vs. B | A vs. B | A vs. B | A vs. B | Funded by Bristol-Myers Squibb, role of funder not reported | FAIR | II. Number screened and eligible not reported, clinical stage not reported
| North America, South America, Europe, South Africa, and Australia | | | | | Not reported | 159/511 (31%) withdrew prior to 48 weeks | Gender: Not reported | Secondary outcomes: Proportion of patients with viral load <50 copies/ml at 48 weeks, change from baseline CD4 count | B: AZT 300 mg bid + 3TC 150 mg bid + NFV 750 mg tid | Percent with HIV-1 RNA level of <400 copies/ml at 48 weeks: 56% vs. 52% (ITT, estimated from graph) | Mean increase in CD4 count: 157 vs. 189 cells/mm^3^ (NS) | Deaths: 3 vs. 2 (sample sizes not clear) | Withdrawals due to adverse events: Not reported | | Number in each arm not reported, open-label
| | | | | | 511 | | Race: Not reported | | | Percent with HIV-1 RNA level of <50 copies/ml at 48 weeks: 32% overall, no difference between groups | | AIDS-defining diseases: None reported | Any adverse events: 89% vs. 86%
| | | | | | | | Viral load: Mean 4.69 vs. 4.74 log_10_ copies/ml | | | | | | Grade 3 or 4 AE: 13% vs. 8%
| | | | | | | | CD4 count: Mean 411cells/mm^3^ | | | | | | Rash (grade 3 or 4): 2% vs. 1%
| | | | | | | | | | | | | | Diarrhea: 57% vs. 58%
| | | | | | | | | | | | | | Diarrhea (grade 3 or 4): 1% vs. 2%
| | | | | | | | | | | | | | Peripheral neuropathy: 25% vs. 11% (p<0.01)
| | | | | | | | | | | | | | Peripheral neuropathy (grade 3 or 4): 2% vs. 0%
| | | | | | | | | | | | | | Pancreatitis: 2 vs. 0%
| | | | | | | | | | | | | | Hematologic abnormalities: More common with B
| | | | | | | | | | | | | | Liver transaminase abnormalities: 43% vs. 14% (p<0.01)
| | | | | | | | | | | | | | Alanine TransaminaseAA15 abnormalities: 39% vs. 15% (p<0.01)
| | | | | | | | | | | | | | Liver abnormalities (3 or 4): Similar
| | | | | | | | | | | | | | Elevation in lipase: 21% vs. 9% (p<0.01)
| | | | | | | | | | | | | | Elevation in lipase (3 or 4): Similar
Gerstoft, 2003^433^ | RCT Multicenter | Compare regimens of 3 NRTIs; 2 PI + 2 NRTI; and 1 PI, 1 NNRTI, plus 2 RTI | 48 weeks | Documented HIV infection, >18 years old, antiretroviral naïve | Pregnancy/lactation, contraindication to study drug, ongoing participation in controlled trials, women of child-bearing age not using safe contraception | Not reported | 180 analyzed | Median age: 36 vs. 36 vs. 40 years | Primary outcome: Proportion of patients with viral load ≤20 copies/ml at week 48 | A: Abacavir 300 mg bid + d4T 40 mg bid + ddI 400 mg qD | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | Boehringer Ingelheim, GlaxoSmithKline, Roche, ‘unconditional support’ | FAIR | II. Number screened and eligible not reported, clinical stage not reported | Arm A added after enrollment already started with arms B and C in another trial that included antiretroviral-experienced patients.
| Denmark | | | | | Not reported | 100/180 (56%) withdrew | Female gender: 24% vs. 23% vs. 28% | Secondary outcomes: Changes in CD4 count, adverse event, medication changes | B: RTV 400 mg bid + SQV 400 mg bid + AZT 300 mg bid + 3TC 150 mg bid | Percent with HIV-1 RNA level <20 copies/ml at 48 weeks: 43% vs. 62% vs. 69% (ITT, p<0.01 for A vs. C and p<0.05 for A vs. B); 59% vs. 87% vs. 59% (on-treatment) | Median increase in CD4 count at week 48: 140 vs. 140 vs. 185 cells/mm^3^ (NS) | Deaths: 2/60 vs. 1/60 vs. 2/50 | Changed at least one component of regimen: 63% vs. 58% vs. 45% (p<0.05 vs. A) | | Open-label, protocol modified after enrollment already started
| | | | | | 182 | | Non-white: 23% vs. 19% vs. 23% | | C: NFV1250 mg bid + NVP 200 mg bid + AZT 300 mg bid + 3TC 150 mg bid | Adjusted OR for viral load <20 copies/ml at week 48 | | New AIDS defining event: 1/60 vs. 2/60 vs. 2/60 | Severe (grade 4) adverse events, including hospitalizations: 13% vs. 7% vs. 12% (NS)
| | | | | | | | Median CD4 count: 161 cells/mm^3^ | | | A vs. B: 0.53 (0.33–0.83) | | | Grade 3–4 adverse events: 28% vs. 17% vs. 26% (NS)
| | | | | | | | Median viral load: 5.0 log_10_ copies/ml | | | A vs. C: 0.25 (0.10–0.59) | | | Abacavir sensitivity suspected: 12% of group A
| | | | | | | | | | | | | | Discontinued due to symptomatic hyperlactatemia: 5/60 (12%) vs. 0/60 vs. 0/60
| | | | | | | | | | | | | | Discontinued due to rash: 7% vs. 0% vs. 8%
Gulick, 2004^435^ | RCT Multicenter | Compare HAART regimens using 3 NRTI, 2 NRTI + 1 NNRTI, and 3 NRTI + 1 NNRTI | 48 weeks, study stopped after mean 32 weeks | HIV-1 infected, no previous antiretroviral therapy, viral load ≥400 copies/ml | Recent immunomodulator or investigational therapy or vaccines, weight less than 40 kg, pregnant or breastfeeding | Not reported | 1,147 analyzed | Mean age: 38 years | Primary outcome: Virologic failure | A: AZT 300 mg bid + 3TC 150 mg bid + abacavir 300 mg bid | A vs. B or C | A vs. B or C | Death: 7/1147 overall | A vs. B or C | NIAID, authors received funding support from various manufacturers | GOOD | II. Number screened and eligible not reported, clinical stage not reported | Study ended early because of higher failure rates in triple NRTI group.
ACTG A5095 | U.S.A. | | | | | Not reported | 7% (83/1,147) had follow-up discontinued | Female gender: 19% | Secondary outcomes: Adverse events, CD4 counts | B: AZT 300 mg bid + 3TC 150 mg bid + EFV 600 mg qD | Virologic failure (2 successive viral load of ≥200 copies/ml at least 16 weeks after randomization): 82/382 (21%) vs. 85/765 (11%) (ITT, p<0.001) | Mean increase in CD4 count at week 48: 174 vs. 173 cells/mm^3^ (p=0.58) | Clinical progression: Not reported | Withdrawal (overall): 83/1147, no significant differences between groups
| | | | | | 1,147 | | Non-white: 40% | | C: AZT 300 mg bid + 3TC 150 mg bid + abacavir 300 mg bid + EFV 600 mg qD | Percent with HIV-1 RNA level <200 copies/ml at week 48: 283/382 (74%) vs. 681/765 (89%) (ITT, p<0.05) | | | Suspected hypersensitivity: 27/382 (7%) vs. 59/765 (8%)
| | | | | | | | Baseline viral load: 4.86 log_10_ copies/ml | | | Percent with HIV-1 RNA level <50 copies/ml at week 48: 233/382 (61%) vs. 635/765 (83%) (ITT, p<0.05) | | | Grade 3 clinical toxic effects: 10% vs. 13%
| | | | | | | | Baseline CD4 count: 234–242 cells/mm^3^ | | | | | | Grade 4 clinical toxic effects: 2% vs. 2%
| | | | | | | | | | | | | | Grade 4 laboratory toxic effect: 8% vs. 10%
Kirk, 1999^432^ | RCT Multicenter | Compare HAART regimens using different PI's in combination with 2 NRTIs | 24 weeks | Documented HIV infection, >18 years old, treating physician found an indication for PI treatment | Contraindication to study drug, more than 14 days of PI treatment, ongoing participation in controlled trials, pregnancy, lactation, women of childbearing age not using safe contraception | Not reported | 284 analyzed (119 antiretroviral naïve) | Median age: 39 years | Primary outcome: Proportion of patients with viral load ≤200 copies/ml or ≤20 copies/ml | A: IDV 800 mg tid + AZT 300 mg bid + 3TC 150 mg bid | A vs. B vs. C (antiretroviral naïve patients only) | A vs. B vs. C (antiretroviral naïve) | A vs. B vs. C | A vs. B vs. C (all patients) | Not reported | FAIR | II. Number screened and eligible not reported, clinical stage not reported | Additional analysis at 48 weeks in antiretroviral naïve patients found no differences between interventions for viral load ≤20 copies/ml; at week 72 a statistically significant difference could be found (p=0.01 for B vs. C, p=0.07 for A vs. C) (Katzenstein, 2000)
Danish Protease Inhibitor Study | Denmark | | | | | Not reported | 75/269 (28%) withdrew | Female gender: 14% | Secondary outcomes: Viral load change (average area under the curve minus baseline), CD4 count, adverse events, medication changes | B: RTV 600 mg bid + AZT 300 mg bid + 3TC 150 mg bid | Percent with HIV-1 RNA level ≤200 copies/ml at 24 weeks: 20/32 (63%) vs. 27/48 (57%) vs. 35/39 (89%), (ITT, p<0.01 for C vs. A or B) | Median increase in CD4 count at week 24: 132 vs. 117 vs. 110 cells/mm^3^(p=0.82) | Deaths: 4/284 overall, no significant differences between groups | Withdrawal (overall): 13.5% vs. 45.3% vs. 20.4% (p<0.001) | | Open-label
| | | | | | 284 (119 antiretroviral naïve) | | Non-white: 9% | | C: RTV 400 mg bid + SQV 400 mg bid + AZT 300 mg bid + 3TC 150 mg bid | Percent with HIV-1 RNA level ≤20 copies/ml at 24 weeks: 12/32 (37.5%) vs. 10/48 (20.8%) vs. 22/39 (56.4%), (ITT, p<0.01 for C vs. A or B) | | New or recurrent AIDS-defining events: 16/284 overall, no significant differences between groups | Withdrawal due to adverse events: 8.3% vs. 36.8% vs. 16.1% (p<0.001)
| | | | | | | | Median CD4 count: 110 cells/mm^3^ | | | | | | Hospitalized due to adverse events: 5.2% vs. 5.2% vs. 2.2% (p=0.54)
| | | | | | | | Median viral load: 5.3 log_10_ copies/ml | | | | | | Grade 3–4 adverse events: 15.6% vs. 25.3% vs. 12.9% (p=0.07)
| | | | | | | | | | | | | | Grade 4 adverse events: 4% vs. 3% vs. 0%
Launay, 2002^476^ | RCT Multicenter | Compare 3-drug regimens with PI vs. NNRTI | 72 weeks | Antiretroviral naïve or prior treatment with AZT, ddI, or ddC, >18 years old, CD4 count >100×106/L, viral load ≥5,000 copies/ml, Karnofsky score >70, acceptable laboratory values | Not reported | Not reported | 144 analyzed | Age: Mean 36 years | Primary outcome: Viral load change at week 72 and adverse events grade 3 or 4 or events leading to discontinuation of therapy | A: NVP 200 mg bid + d4T 40 mg bid + IDV 1000 mg tid (n=73) | A vs. B | A vs. B | A vs. B | A vs. B | Funded by Agence Nationale de Recherches sur le SIDA, Bristol-Myers Squibb, Boerhinger Ingelheim, and Merck Sharp & Dhome, role of funders not reported | FAIR | II. Some antiretroviral experienced patients, 69% CDC stage A, number screened and eligible not reported
ANRS 081 | France | | | | | Not reported | 47/144 (33%) withdrew prior to 72 weeks | Gender: 22% female | Secondary outcomes: Proportion of patients with viral load <200 and <20 copies/ml at week 72, change in CD4 count, HIV-1 related AIDS-definig events, time to discontinuation of therapy, plasma drug concentrations, resistance outcome by genotypic and phenotypic analysis, and adherence to therapy | B: 3TC 150 mg bid + d4T 40 mg bid + IDV 800 mg tid (n=71) | Percent with HIV-1 RNA level of <200 copies/ml at 72 weeks: 63% vs. 86% (ITT, p=0.002), 78% vs. 93% (on-treatment) | Median increase in CD4 cell count: 198 vs. 242 cells/mm^3^ (p=0.08) | Deaths: None reported | Withdrawal due to adverse events: 34/73 (46%) vs. 18/72 (25%) | | Open-label
| | | | | | 145 | | Non-white race: Not reported | | | Percent with HIV-1 RNA level of <20 copies/ml at 72 weeks: 52% vs. 79% (ITT), 62% vs. 86% (on-treatment) | | AIDS-defining diseases: None reported | Withdrawal due to adverse events or adverse events grade 3 or 4: 38/73 vs. 28/72
| | | | | | | | Viral load: Mean 4.76 log_10_ copies/ml | | | | | | Grade 3 or 4 adverse events: 32/73 vs. 21/72
| | | | | | | | CD4 count: Mean 380 cells/mm^3^ | | | | | | Rash: 14/73 (19%) vs. 1/72 (1.4%)
| | | | | | | | CDC stage A: 69% | | | | | | Nephrolithiasis: 6/73 vs. 14/72
| | | | | | | | Prior AZT, ddI, or ddC therapy: 21%
Maggiolo, 2003^477^ | RCT Single center | Compare once-daily HAART regimen to 2 twice-daily regimens | 52 weeks | HIV-1 infected, antiretroviral naïve, age >18 years old, CD4 count <500 cells/mm^3^, viral load >10,000 copies/ml | Pregnant or breast-feeding | Not reported | 102 analyzed | Mean age: 37–40 years | Primary outcome: Proportion of patients with viral load <50 copies/ml at week 52 (ITT) | A: ddI 400 mg qD + 3TC 300 mg qD + EFV 600 mg qD | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | Withdrawal (overall): 5/34 (15%) vs. 5/34 (15%) vs. 16/34 (47%) | Not reported | FAIR | II. High proportion of CDC stage C
| Italy | | | | | Not reported | 25% (26/102) withdrew | Female gender: 16% | Secondary outcomes: On-treatment viral response, CD4 counts, adverse events | B: AZT 300 mg bid + 3TC 150 mg bid + EFV 600 mg qD | Percent with HIV-1 RNA level <50 copies/ml at week 52: 26/34 (77.4%) vs. 26/34 (77.4%) vs. 17/34 (50%) (ITT, p=0.02); 30/34 (88.9%) vs. 29/34 (85.7%) vs. 20/34 (60%) (on-treatment, p=0.02) | Mean increase in CD4 count at week 52: 194 vs. 183 vs. 165 cells/mm^3^ | Death: None reported | Withdrawal due to adverse event (grade 3–4): 3/34 (9%) vs. 4/34 (12%) vs. 9/34 (26%) | | Open-label
| | | | | | 102 | | Race: Not reported | | C: AZT 300 mg bid + 3TC 150 mg bid + NFV 1250 mg bid | | | Disease progression: 0/34 vs. 1/34 vs. 1/34
| | | | | | | | Mean CD4 count: 169–184 cells/mm^3^
| | | | | | | | Mean viral load: 5.16–5.22 log_10_ copies/ml
| | | | | | | | CDC stage C: 62%
Martinez-Picado, 2003^478^ | RCT Multicenter | Compare 2 standard 3-drug regimens with alternating 3-drug regimens every 3 months | 48 weeks | Antiretroviral naïve, >18 years old, viral load >400 copies/ml, negative pregnancy test in women | None reported | Not reported | 153 analyzed for primary outcome (8 excluded because they did not have viral load <400 copies/ml after week 24) | A vs. B vs. C | Primary outcome: Time to virologic failure (first plasma HIV-1 RNA level >400 copies/ml between weeks 24 and 48 after viral load had decreased to <400 copies/ml by week 24) | A: ddI 400 mg qD + d4T 40 mg bid + EFV 600 qD | A vs. B | Mean CD4 count increased by average of 1.9 cells/mm^3^ per week in all groups, no significant differences | Deaths: None reported | A vs. B vs. C | Fudning by Spanish Ministry of Science and Technology, NIH, Roche, Bristol-Myers Squibb, and GlaxoSmithKline, industry provided unrestricted grants | FAIR | I. Low proportion with AIDS
SWATCH | Spain and Argentina | | | | | Not reported | 45/153 (29%) withdrew prior to 48 weeks | Mean age: 52 vs. 54 vs. 55 | Secondary outcomes: Proportion of patients with viral load <400 and <40 copies/ml, time to treatment discontinuation, due to all causes, due to causes other than virologic failure, and due to adverse events | B: AZT 300 mg bid + 3TC 150 mg bid + NFV 1250 mg bid | Percent with HIV-1 RNA level of <400 copies/ml at 48 weeks: 67% vs. 60% (ITT, p>0.2, estimated from graph), odds ratio 1.01 [CI, 0.9 to 1.2], p>0.2 | | AIDS-defining illnesses: None reported | Treatment change due to adverse events: 5/50 (10%) vs. 7/49 (14%) vs. 9/54 (17%) (p>0.2 for A vs. B and for A or B vs. C) | | Open-label
| | | | | | 161 | | Female gender (%): 14% vs. 30% vs. 21% | | | Percent with HIV-1 RNA level of <50 copies/ml at 48 weeks: Odds ratio 1.04 [CI 0.9 to 1.2], p>0.2 | | Quality of life score (5-point scale adapted from Medical Outcomes Study-HIV Questionnaire): 4.3 (A or B) vs. 4.5 (C) (NS) | Time to premature treatment discontinuation due to adverse events (events/1000 person-weeks): 2.7 (A or B) vs. 3.8 (C) (p>0.2)
| | | | | | | | Non-white race: Not reported | | | Virologic failure: 10/50 (20%) vs. 10/49 (20%) (ITT, p>0.2), 8/50 (16%) vs. 7/49 (14%) (on-treatment, p>0.2) | | | Rates of other adverse events not reported
| | | | | | | | Median viral load (log_10_ copies/ml): 4.5 vs. 4.8 vs. 4.7 | | | C vs. A or B
| | | | | | | | Median CD4 count: 329 vs. 360 vs. 316 cells/mm^3^ | | | Percent with HIV-1 RNA level of <400 copies/ml at 48 weeks: 67% vs. 63% (ITT, p=0.009, estimated from graph), odds ratio 1.2 [CI, 1.1 to 1.4], p=-.009
| | | | | | | | AIDS (%): 7 vs. 7 vs. 8 | | | Percent with HIV-1 RNA level of <50 copies/ml at 48 weeks: 37/54 (67%) vs. 61/99 (58%) [odds ratio 1.2, CI 1.0 to 1.3]
| | | | | | | | | | | Virologic failure: 3/54 (6%) vs. 20/99 (20%) (ITT, p=0.014), 0/54 (0%) vs. 15/99 (15%) (on-treatment, p=0.002)
Matheron, 2003^479^ | RCT Multicenter | Compare 3-drug regimen of NRTI's with a 3-drug regimen containing a PI | 48 weeks | Antiretroviral naïve, aged ≥18 years, CDC group A or B, viral load 1,000 to 500,000 copies/ml, hemoglobin >10.0 g/dl (men) and 9.0 g/dl (women), neutrophil count >750×10^6^/l, platelet count >75,000×10^6^/l, ALT and AST <2 times the upper limit of normal, creatinine <20 mg/l, amylase <2 times the upper limit of normal, hyperglycemia or hypertriglyceridemia not deemed clinically relevant | Acute HIV infection, history of AIDS-defining event (category C), previous antiretroviral treatment, cytotoxic chemotherapeutic or immunomodulating agents, or radiation therapy within 6 months, pregnant or breastfeeding women or women without efficacious contraception | Not reported | 186 analyzed | Age: median 34 years | Primary outcome: Proportion of patients with viral load <50 copies/ml at week 48 | A: AZT 300 mg/3TC 150 mg bid + abacavir 300 mg bid | A vs B | A vs. B | A vs. B | A vs. B | GlaxoSmithKline, role of funder not reported | FAIR | II. Number screened or eligible not reported, included CDC stage A or B (proportions not reported)
CNAF3007 | France | | | | | Not reported | 44/195 (23%) withdrew | Gender: 33% female | Secondary outcomes: Proportion with viral load <50 copies/ml at week 24, change in viral load and CD4 cell counts from baseline, and clinical progression to CDC group B or C, safety and tolerance | B: AZT 300 mg/3TC 150 mg bid + NFV 750 mg tid | Percent with HIV-1 viral load <50 copies/ml at week 48: 54/95 (57%) vs. 53/91 (58%) (ITT, p=0.85), 64/95 (67%) vs. 64/91 (65%) (ITT including allowed switch, p=0.71), 50/63 (79%) vs. 52/65 (80%) (on-treatment, p=0.93) | Median CD4 cell count increase: 110 vs. 120 cells/mm^3^ (ITT including allowed switch, p=0.687), 110 vs. 130 cells/mm^3^ (on-treatment, p=0.359) | Progression from group A to group B: 2/77 vs. 1/76 | Discontinuation of at least one study drug due to adverse events: 15/95 (16%) vs. 15/91 (16%) | | Open-label
| | | | | | 195 | | Race: Not reported | | | | | Progression from group B to group C: 0/21 vs. 1/20 | Reported in greater than 10% (A): nausea/vomiting (40%)
| | | | | | | | Viral load: Median 4.2 log_10_ copies/ml | | | | | | Reported in greater than 10% (B): diarrhea (47%), nausea/vomiting (33%), abdominal discomfort/pain (11%)
| | | | | | | | CD4 count: Median 387 vs. 449 cells/mm^3^ (p not reported) | | | | | | Treatment-limiting adverse events: 17/95 (18%) vs. 25/91 (27%)
| | | | | | | | | | | | | | Treatment-limiting nausea/vomiting: 5% vs. 11%
| | | | | | | | | | | | | | Treatment-limiting diarrhea: 1% vs. 5%
| | | | | | | | | | | | | | Treatment-limiting leukopenia: 6% vs. 2%
| | | | | | | | | | | | | | Treatment-limiting anemia: 3% vs. 0%
| | | | | | | | | | | | | | Possible abacavir hypersensitivity: 4/95 (4%) vs. 0/91
Murphy, 2003^481^ | RCT Multicenter | Compare different doses of atazanavir versus NFV in combination therapy | 48 weeks | Antiretroviral naïve, age>18 years old, viral load ≥2000 copies/ml, and CD4 count ≥100 cells/mm^3^ | Newly diagnosed HIV-1-related opportunistic infection, suspected primary HIV-1 infection, history of acute or chronic pancreatitis, proven or suspected hepatitis, signs or symptoms of peripheral neuropathy grade 2 or higher, pregnant women, elevated renal or liver tests | Not reported | 467 analyzed | Age: Mean 35 years | Primary outcomes: Mean change in viral load at week 48 | A: Atazanavir 400 mg qD + 3TC 150 mg bid + d4T 40 mg bid | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | Withdrawals (overall): 12% | Not reported | FAIR. | II. Number screened and eligible not reported
Study AI424-008 | International | | | | | Not reported | 3 did not initiate treatment | Gender: 37% female | Secondary outcomes: Viral load <400 and <50 copies/ml at week 48; changes in CD4 counts, adverse events | B: Atazanavir 600 mg qD + 3TC 150 mg bid + d4T 40 mg bid | Percent with HIV-1 RNA level of <400 copies/ml at week 48: 64% vs. 67% vs. 53% (ITT, p<0.05 for B vs. C), 74% vs. 75% vs. 60% (on-treatment, p<0.05 for A or B vs. C) | Mean CD4 cell count increase at week 48: 234 vs. 243 vs. 211 (NS) | Deaths: 0.5% (1/181) vs. 1% (2/1950 vs. 0% (0/91) | A vs. B vs. C | | Blinding only to atazanavir dose
| | | | | | 467 randomized | 12% discontinued study early | Non-white race: 45% | | C: Nelfinavir 1250 mg bid + 3TC 150 mg bid + d4T 40 mg bid | Percent with HIV-1 RNA level of <50 copies/ml at week 48: 35% (63/181) vs. 36% (71/195) vs. 34% (31/91) (ITT, NS), 40% vs. 41% vs. 39% (on-treatment, NS) | | Clinical progression: None reported | Withdrawal due to adverse events: 5% (9/178) vs. 7% (14/191) vs. 4% (4/91)
| | | | | | | | Viral load: Mean 4.74 log_10_ copies/ml | | | | | | Diarrhea: 20% vs. 15% vs 56% (p<0.0001 for A or B vs. C)
| | | | | | | | CD4 count: Mean 295 cells/mm^3^ | | | | | | Jaundice: 11% vs. 20% vs. 0% (p<0.0001 for A or B vs. C)
| | | | | | | | AIDS diagnosis: 11% | | | | | | Headache: 25% vs. 27% vs. 26%
| | | | | | | | | | | | | | Peripheral neurological symptoms: 18% vs. 22% vs. 21%
| | | | | | | | | | | | | | Rash: 22% vs. 17% vs. 19%
| | | | | | | | | | | | | | Nausea: 21% vs. 18% vs. 18%
| | | | | | | | | | | | | | Lipodystrophy: 4% vs. 4% vs. 2%
| | | | | | | | | | | | | | Elevated bilirubin (grade 3 to 4): 41% vs. 58% vs 4%
| | | | | | | | | | | | | | Lactic acidosis: 2% (3/178) vs. 2% (4/191, 2 deaths) vs. 0% (NS)
Murphy, 2001^480^ | RCT Multicenter | Compare different doses of lopinavir combined with low-dose RTV in 4-drug regimens | 48 weeks | Antiretroviral naïve, age>18 years old, viral load >5,000 copies/ml, no acute illness, Karnofsky score ≥70, and able to comply with study procedures | Hemoglobin <8.6 g/dl, neutrophil count <106 cells/l, platelet count <50 000×106/l, ALT or AST >2.5 times the upper limit of normal, creatinine > 1.5 times the upper limit of normal, fasting triglycerides >400 mg/dl, women pregnant or lactating, coinfection with hepatitis B and/or C, women not using barrier birth control methods | Not reported | 100 analyzed | Age: Mean 35 years | Primary outcomes: Viral load <400 copies/ml at week 24 (ITT and on-treatment) | Group I | A vs. B | A or B | Death: None reported | Withdrawal due to adverse events: 0% | Funding by Abbott Laboratories, role of funder not reported | GOOD | II. Number screened and eligible not reported, clinical stage not reported
| USA | | | | | Not reported | 7% discontinued study early | Gender: 4% female | Secondary outcomes: Loss of virologic response, adverse events | A: Lopinavir 200 mg/RTV 100 mg bid + d4T 40 mg bid +3TC 150 mg bid | Percent with HIV-1 RNA level of <400 copies/ml at 48 weeks: 100% vs. 81% (ITT, p=0.226), 100% vs. 93% (on-treatment, NS) | Mean CD4 cell count increase at week 48: 244 cells/mm^3^ | New AIDS-defining events: One (group not reported) | A vs. B (at least moderate in severity)
| | | | | | 32 enrolled in group I | | Non-white race: 30% | Assessed monthly for first 24 weeks, then quarterly | B: Lopinavir 400 mg/RTV 100 mg bid + d4T 40 mg bid + 3TC 150 mg bid | Percent with HIV-1 RNA level of <50 copies/ml at 48 weeks: 100% (16/16) vs. 50% (8/16) (ITT, p=0.002), 100% vs. 57% (on-treatment) | C or D | | Nausea: 13% vs. 0%
| | | | | | 68 enrolled in group II | | Viral load: Mean 4.9 log_10_ copies/ml | | Group II | C vs. D | Mean CD4 cell count increase at week 48: 213 cells/mm^3^ | | Diarrhea: 2/16 (13%) vs. 4/16 (25%)
| | | | | | | | CD4 count: Mean 398 cells/mm^3^ (group I) and 310 cells/mm^3^ (group II) | | C: Lopinavir 400/RTV 100 mg bid + d4T 40 mg bid + 3TC 150 mg bid | Percent with HIV-1 RNA level of <400 copies/ml at 48 weeks: 91% vs. 73% (ITT, NS), 100% vs. 80% (on-treatment, p=0.01) | | | Abnormal stools: 3/16 (19%) vs. 3/16 (19%)
| | | | | | | | Time since diagnosis: Mean 2.3 years | | D: Lopinavir 400/RTV 200 mg bid + d4T 40 mg bid + 3TC 150 mg bid | Percent with HIV-1 RNA level of <50 copies/ml at 48 weeks: 86% vs. 73% (ITT, NS), 94% vs. 80% (on-treatment, NS) | | | Vomiting: 1/16 (6%) vs. 0%
| | | | | | | | | | | | | | Asthenia: 1/16 (6%) vs. 2/16 (13%)
| | | | | | | | | | | | | | Headache: 1/16 (6%) vs. 2/16 (13%
| | | | | | | | | | | | | | Triglycerides (>750 mg/dl): 3/16 (19%) vs. 2/16 (13%)
| | | | | | | | | | | | | | Total cholesterol (>300 mg/dl): 2/16 (13%) vs. 1/16 (6%)
| | | | | | | | | | | | | | ALT or AST (>5 times upper limit of normal): 0% vs. 0%
| | | | | | | | | | | | | | C vs. D (at least moderate in severity)
| | | | | | | | | | | | | | Nausea: 3/35 (9%) vs. 10/33 (33%) (p=0.031)
| | | | | | | | | | | | | | Diarrhea: 6/35 (17%) vs. 8/33 (24%)
| | | | | | | | | | | | | | Vomiting: 0% vs. 4/33 (12%) (p=0.05)
| | | | | | | | | | | | | | Asthenia: 2/35 (6%) vs. 2/33 (6%)
| | | | | | | | | | | | | | Headache: 2/35 (6%) vs. 2/33 (6%)
| | | | | | | | | | | | | | Triglycerides (>750 mg/dl): 2/35 (6%) vs. 5/33 (15%)
| | | | | | | | | | | | | | Total cholesterol (>300 mg/dl): 2/35 (6%) vs. 5/33 (15%)
| | | | | | | | | | | | | | ALT or AST (>5 times upper limit of normal): 7/35 (20%) vs. 1/33 (3%)
Nunez, 2002^482^ | RCT Single center | Compare three-drug regimens containing EFV and NVP | 48 weeks | Documented HIV infection, age >18 years, antiretroviral naïve, CD4 count >100 cells/mm^3^, viral load 500 to 100,000 copies/ml, no major organ failure, standard prophylaxis for opportunistic infections, negative pregnancy test in women of child-bearing age, and no current high alcohol intake or substance abuse | None reported | Not reported | 76 analyzed | Median age: 35 years | Primary outcome: Proportion of patients with HIV viral load <copies/ml at 48 weeks, and drug-related toxicities causing discontinuation of the NNRTI | A: NVP 400 mg qD + d4T 40 mg bid + ddI 400 mg qD | A vs. B | A vs. B | A vs. B | A vs. B | Asociacion Investigacion y Educacion en SIDA and the Comunidad Autonoma de Madrid, role of funder not reported | FAIR | II. Number screened and eligible not reported, clinical stage not reported, high proportion of patients with hepatitis C
SENC | Spain | | | | | Not reported | 21/67 (31%) withdrew | Female gender: 22% | Secondary outcomes: Mean changes in CD4 counts, overall safety, degree of adherence, and adverse events | B: EFV 600 mg qD + d4T 40 mg bid + ddI 400 mg qD | Percent with HIV-1 RNA level <50 copies/ml at 48 weeks: 23/36 (64%) vs. 23/31 (74%) (ITT, p=0.43), 23/26 (88%) vs. 23/23 (100%) (on-treatment, p=0.24) | Mean (median) increase in CD4 count at week 48: 119 (100) vs. 117 (58) cells/mm^3^ | Deaths: None reported | Discontinuation of NVP or EFV due to adverse events: 3/36 (8.3%) vs. 4/31(13%) | | Open-label
| | | | | | 67 enrolled | | Race: Not reported | | | | | AIDS-defining diseases: None reported | Rash: 4/35 (11%) vs. 3/29 (10%)
| | | | | | | | Median viral load: 22,789 copies/ml | | | | | | CNS symptoms: 0/35 vs. 12/29 (41%)
| | | | | | | | Median CD4 count: 374 cells/mm^3^ | | | | | | Peripheral neuropathy: 2/35 (6%) vs. 3/29 (10%)
| | | | | | | | Positive anti-hepatitis C antibody: 40% | | | | | | Gastrointestinal symptoms: 2/35 (6%) vs. 3/29 (10%)
| | | | | | | | Positive hepatitis B surface antigen: 4% | | | | | | Pancreatitis: 0/35 (0%) vs. 1/29 (3%)
| | | | | | | | AIDS: 10% | | | | | | Lipodystrophy: 1/35 (3%) vs. 5/29 (17%)
| | | | | | | | | | | | | | Gynecomastia: 0/35 (0%) vs. 1/29 (3%)
| | | | | | | | | | | | | | Elevated liver enzymes: 9/35 (26%) vs. 5/29 (17%)
| | | | | | | | | | | | | | Elevated liver enzymes (grades 3 or 4): 5/35 (14%) vs. 3/29 (10%)
| | | | | | | | | | | | | | Cholesterol (>300 mg/dl): 1/35 (3%) vs. 5/29 (17%)
| | | | | | | | | | | | | | Triglycerides (>750 mg/dl): 0/35 (0%) vs. 1/29 (3%)
Podzamczer, 2002^483^ | RCT Multicenter | Compare NFV vs. NVP in combination with AZT/3TC | 12 months | Antiretroviral naïve, viral load >1,500 copies/ml, without AIDS-defining diseases | Not reported | Not reported | 142 analyzed | Age: 35 vs. 36 years | Primary outcome: Viral load <200 copies/ml at 12 months | A: AZT 300 mg/3TC 150 mg bid + NFV 1250 mg bid | A vs. B | A vs. B | A vs. B | A vs. B | Funded by Glaxo, Roche, Boehringer Ingelheim, and fundacio August Pi i Sunyer, role of funders not reported | FAIR | I. Only patients without AIDS-defining illness
Combine Study | Spain and Argentina | | | | | Not reported | 44% withdrew prior to 1 year | Gender: 33% vs. 18% female (p=0.043) | Secondary outcomes: Viral load <20 copies/ml at 12 months, change in CD4 counts, HIV-related complications, and discontinuation of therapy due to adverse events | B: AZT 300 mg/3TC 150 mg bid + NVP 200 mg bid | Percent with HIV-1RNA level of <200 copies/ml at 12 months: 60% vs. 75% (ITT, p=0.06), 80% vs. 92% (on-treatment, p=0.12) | Mean increase in CD4 count: 173 vs. 162 cells/mm^3^ (p=0.01) | Deaths: None | Withdrawal due to adverse events: 15/70 (21%) vs. 18/72 (25%) (p>0.2) | | Open-label
| | | | | | 142 | | Non-white race: Not reported | | | Percent with HIV-1 RNA level of <20 copies/ml at 12 months: 50% vs. 65% (ITT, p=0.06), 71% vs. 79 (on-treatment, p>0.2) | | AIDS-defining disease: 0/70 vs. 1/72 | Diarrhea (any severity): 25/70 (36%) vs. 0/72 (0%) (p<0.0001)
| | | | | | | | Viral load: Mean 5.21 vs. 5.07 log_10_ copies/ml | | | | | | Rash (any severity): 1/70 (1.4%) vs. 10/72 (14%) (p=0.005)
| | | | | | | | CD4 count: Mean 347 vs. 375 cells/mm^3^ | | | | | | Neutropenia (any severity): 10/70 (14%) vs. 26/72 (36%) p=0.003
| | | | | | | | Risk group homosexual: 19% vs. 38% (p=0.013) | | | | | | ALT elevation (any severity): 20/70 (29%) vs. 31/72 (43%)
| | | | | | | | | | | | | | Alkaline phosphatase elevation (any severity): 28/70 (40%) vs. 38/72 (53%)
| | | | | | | | | | | | | | Grade 3 or 4 adverse events or lab abnormalities
| | | | | | | | | | | | | | Diarrhea: 3/70 vs. 0/72
| | | | | | | | | | | | | | Vomiting: 0 vs. 0
| | | | | | | | | | | | | | Nausea: 0 vs. 0
| | | | | | | | | | | | | | Other GI: 1/70 vs. 0/72
| | | | | | | | | | | | | | Asthenia: 0 vs. 0
| | | | | | | | | | | | | | Depression/anxiety: 1/70 vs. 0/72
| | | | | | | | | | | | | | Rash: 0/70 vs. 1/72
| | | | | | | | | | | | | | Hemoglobin: 0 vs. 1/72
| | | | | | | | | | | | | | Neutropenia: 0 vs. 3/72
| | | | | | | | | | | | | | Thrombocytopenia: 1/70 vs. 0/72
| | | | | | | | | | | | | | ALT elevation: 5/70 vs. 7/72
| | | | | | | | | | | | | | Alkaline phosphatase elevation: 0/70 vs. 3/72
| | | | | | | | | | | | | | Triglyceride elevation: 0 vs. 0
| | | | | | | | | | | | | | Cholesterol elevation: 4/70 vs. 3/72
| | | | | | | | | | | | | | Serum amylase elevation: 2/70 vs. 4/72
| | | | | | | | | | | | | | Creatinine: 0 vs. 0
Robbins, 2003^484^ | RCT Multicenter | Compare pairs of sequential three-drug regimens | Mean 2.3 years | HIV-1 RNA >500 copies/ml, prior antiretroviral therapy for <7 days, no serious acute illness or lab abnormalities for 14 days prior to entry | None described | Not reported | 7/987 received no intervention | Age: Median 36 years | Primary endpoints: failure of second sequential three-drug regimen or premature discontinuation of study medication. | A: ddl 400 mg qD (250 mg qD if body weight <60 kg), d4T 40 mg bid (30 mg bid if body weight <60 kg), and EFV 600 mg qD followed by AZT 300 mg bid, 3TC 150 mg bid, and NFV 1250 mg bid | Reached primary endpoint (including discontinuations) | Median increase | Deaths | See Shafer, 2003 | National Institute of Allergy and Infectious Disease, National Center for Reseach Resources, HIV Clinical Research Program, Universtiy of Alabama at Birmingham. | GOOD Blinded to EFV and NFV but not to other antiretrovirals | II. Numbers screened and eligible not reported, and proportion of asymptomatic patients at time of study entry not reported | Initial therapy with AZT, 3TC, and EFV appeared superior.
| USA and Italy | | | | | Not reported | 620 analyzed | Gender: 19% female | Secondary endpoints: length of time to failure of the initial regimen, times to first and second virologic failures, time to viral suppression, CD4 count at weeks 48, 96, and 144, time to initial viral suppression, and toxic affects. | B: ddl 400 mg qD (250 mg qD if body weight <60 kg), d4T 40 mg bid (30 mg bid if body weight <60 kg), and NFV1250 mg bid followed by AZT 300 mg bid, 3TC 150 mg bid, and EFV 600 mg qD | A, B, C, or D: 272/620 (44%) | No significant differences between interventions (median rise 285 cells/mm^3^ at week 144). | A, B, C, or D: 6/620 (1%) | Time to first serious toxic effect | Authors were consultants for manufacturers of drugs studies, none were directly employed.
| | | | | | 987 enrolled including patients on 4-drug regimens | 192/620 (31%) withdrew (not including those meeting primary endpoints) but analyzed | Non-white: 53% | Assesssed at weeks 4, 8, 12, 16, 20, 24, and every 8 weeks thereafter. | C: AZT 300 mg bid, 3TC 150 mg bid, and EFV 600 mg qD followed by ddl 400 mg qD (250 mg qD if body weight <60 kg), d4T 40 mg bid (30 mg bid if body weight <60 kg), and NFV 1250 mg bid | 80 regimen failures | | AIDS-defining events | B or D vs. A or C: Favors B or D, p<0.001 (HR not reported) | Role of funder otherwise not described.
| | | | | | Not clear number enrolled in 3-drug regimens | | Viral load: Median 4.9 log_10_ copies/ml | | D: AZT 300 mg bid, 3TC 150 mg bid, and NFV 1250 mg bid followed by ddl 400 mg qD (250 mg qD if body weight <60 kg), d4T 40 mg bid (30 mg bid if body weight <60 kg), and EFV 600 mg qD | 192 premature discontinuations | | 20/620 (3%), no significant differences reported | Time to first symptom or diagnosis of peripheral neuropathy
| | | | | | | | CD4: Median 280 cells/mm^3^ | | | Time to primary endpoint | | | B or D vs. A or C: Favors B or D, p<0.001
| | | | | | | | | | | C vs. D: HR 0.71 (95% CI, 0.48, 1.06) | | | Self-reported adherence
| | | | | | | | | | | A vs. B: HR 1.29 (95% CI, 0.88, 1.89) | | | 97.6–98.2%
| | | | | | | | | | | C vs. A: HR 0.68 (95% CI, 0.46, 1.01)
| | | | | | | | | | | D vs. B: HR 1.22 (95% CI, 0.84, 1.79)
| | | | | | | | | | | Two virologic failures
| | | | | | | | | | | C vs. D: HR 0.56 (95% CI, 0.29, 1.09)
| | | | | | | | | | | C vs. A: HR 0.47 (95% CI, 0.24, 0.89)
| | | | | | | | | | | A vs. B: HR 1.70 (95% CI, 0.95, 3.05)
| | | | | | | | | | | D vs. B: HR 1.43 (95% CI, 0.78, 2.60)
| | | | | | | | | | | Failure of first regimen
| | | | | | | | | | | C vs. D: HR 0.39 (95% CI, 0.24, 0.64)
| | | | | | | | | | | C vs. A: HR 0.35 (95% CI, 0.22, 0.57)
| | | | | | | | | | | A vs. B: HR 0.88 (95% CI, 0.61, 1.29)
| | | | | | | | | | | D vs. B: HR 0.82 (95% CI, 0.56, 1.20)
| | | | | | | | | | | Time to viral suppression (<50 copies/ml) at 24 weeks
| | | | | | | | | | | A or C vs. B or D: Favors A or C, p<0.001 (HR not reported)
| | | | | | | | | | | C or D vs. A or B: Favors C or D, p=0.09 (HR not reported)
Rodriguez-French, 2004^485^ | RCT Multicenter | Compare HAART regimens with different protease inhibitors | 48 weeks | HIV-1 infected, antiretroviral naïve (<4 weeks therapy NRTI and no NNRTI or PI), age >18 years old, viral load >5,000 copies/ml | Significant medical conditions, recent pancreatitis or hepatitis, pregnant or lactating, using excluded medications, radiation therapy or cytotoxic therapy, significant abnormalities in lab values | 341 screened | 249 analyzed | Median age: 37 years | Primary outcome: Proportion of patients with viral load <400 copies/ml at 48 weeks | A: Fosamprenavir 1400 mg bid + abacavir 300 mg bid + 3TC 150 mg bid | A vs. B | A vs. B | No deaths reported | A vs. B | GlaxoSmithKline Research and Development, role not reported | FAIR | I. Relatively few patients CDC stage C
NEAT | United States, Panama, Puerto Rico, and South Africa | | | | | 251 eligible | 18/249 (7%) lost to follow-up | Female gender: 31% | Secondary outcomes: CD4 count, change in viral load, adverse events | B: NFV 1250 mg bid + abacavir 300 mg bid + 3TC 150 mg bid | Percent with HIV-1 RNA level <400 copies/ml at week 48:109/166 (66%) vs. 40/83 (48%) (ITT, missing data = failure) (95% CI for difference 5–30%); 94% (104/111) vs. 40/42 (95%) (on-treatment) | Median CD4 count increase: 201 vs. 216 cells/mm^3^ | No AIDS-defining events reported | Withdrawal (overall): 46% vs. 30% | | Open-label
| | | | | | 251 enrolled | | Non-white: 76% | | | Percent with HIV-1 RNA level <50 copies/ml at week 48: 96/166 (58%) vs. 35/83 (42%) (ITT, missing data=failure) (95% CI for difference 3–28%); 93/111 (84%) vs. 35/42 (83%) (on-treatment) | | | Withdrawal (adverse events): 5% (9/166) vs. 6% (5/83)
| | | | | | | | CDC stage C: 20% | | | | | | Adverse event grade >=2: 50/166 (30%) vs. 28/83 (34%)
| | | | | | | | Median viral load: 4.83 log_10_ copies/ml | | | | | | Grade 2–4 rash: 12/166 (7%) vs. 2/83 (2%)
| | | | | | | | Median CD4 count: 212 cells/mm^3^ | | | | | | Grade 2–4 abacavir hypersensitivity: 15/166 (9%) vs. 4/83 (5%)
| | | | | | | | | | | | | | Grade 3–4 laboratory adverse lipase elevation: 8% vs. 4%
Saag, 2004^486^ | RCT Multicenter | Compare 3-drug regimens with emtricitabine vs. stavudine | 60 weeks | ≥18 years old, viral load >5,000 copies/ml, antiretroviral naïve, Karnofsky score >80 | Significant hepatic, hematologic, or pancreatic abnormalities | 820 screened | 9 did not receive study drug | Age: Mean 36 years | Primary outcomes: Viral load <50 copies/ml at weeks 24, 48 and 60 | A: Emtricitabine 200 mg qD + ddI 400 mg qD + EFV 600 mg qD | A vs. B | A vs. B | A vs. B | A vs. B | Funding by Gilead Sciences Inc, role not reported | GOOD | I. Few patients with CDC stage C disease
FTC-301A | North America, Latin America, and Europe | | | | | 647 eligible | 571 analyzed | Gender: 15% female | Secondary outcomes: Virological failure, CD4 count change from baseline, genotypic resistance | B: d4T 40 mg bid + ddI 400 mg qD + EFV 600 mg qD | Percent with HIV-1 RNA level of <50 copies/ml at 48 weeks: 78% vs. 59% (ITT, p<0.001) | Mean CD4 cell count increase at week 48: 168 vs. 134 cells/mm^3^ (p=0.15) | Death: 0 vs. 2/285 (0.7%) | Withdrawal due to adverse events: 6.7% vs. 13.0%
| | | | | | 580 randomized | 26% discontinued study | Non-white race: 48% | | | Percent with HIV-1 RNA level of <50 copies/ml at 60 weeks: 76% vs. 54% (ITT, p<0.001) | | Clinical progresssion: 5/286 (1.7%) vs. 10/285 (3.5%) | Treatment-limiting adverse events: 7% vs. 15% (p=0.005)
| | | | | | | | Viral load: Mean 4.8 log_10_ copies/ml | | | | | | ‘Serious’ adverse event: 8% vs. 14% (p=0.13)
| | | | | | | | CD4 count: Mean 312 vs. 324 cells/mm^3^ | | | | | | Grade 3 or 4 laboratory abnormality: 34% vs. 38%
| | | | | | | | History of CDC class C events: 2.4% vs. 3.2% | | | | | | Grade 3 or 4 amylase increase: 5% vs. 10% (p=0.02)
Saag, 2001^487^ | RCT Multicenter | Compare 3-drug regimens with 2 different NFV doses | 24 weeks initial intervention, 24 additional weeks extension | >13 years old, viral load ≥15,000 copies/ml, less than one month of AZT and no other antiretroviral therapy, Karnofsky ≥70 | Major or unstable illness, acute opportunistic infection, acute pancreatitis, significantly elevated renal tests, liver tests, or hematologic test; active drug users, pregnant or nursing women, patients with procreative potential not practicing single-barrier contraception, immune modulators or vaccines within last month | Not reported | 297 analyzed | Age: Mean 37 years | Primary outcomes: Viral load <400 copies/ml at week 24, viral load <50 copies/ml at week 24, and CD4 counts | A: NFV 750 mg tid + AZT 200 mg tid + 3TC 150 mg bid | A vs. B | A vs. B | A vs. B | A vs. B | Funding by Agouron Pharmaceuticals, role of funder not reported | GOOD | II. Number screened and eligible not reported, high proportion of patients with HIV-related conditions
Agouron study 511 | USA | | | | | Not reported | 18% discontinued prior to week 24 | Gender: 11% female | | B: NFV 500 mg tid + AZT 200 mg tid + 3TC 150 mg bid | Percent with HIV-1 RNA level of <400 copies/ml at 24 weeks: 67% vs. 50% (ITT) | Mean CD4 cell count increase at week 24: 148 vs. 135 cells/mm^3^ (estimated from graph) | Death: None reported | Withdrawal due to adverse events: 2–4%
| | | | | | 316 | | Non-white race: Not reported | | C: AZT 200 mg tid + 3TC 150 mg bid (results of this arm not reported here, patients completing 24 weeks randomized into arms A or B) | Percent with HIV-1 RNA level of <50 copies/ml at 24 weeks: 55% vs. 30% (ITT, p<0.001) | Mean CD4 cell count increase at week 48: 190 vs. 188 cells/mm^3^ (estimated from graph) | New AIDS-defining events: None reported | Diarrhea: 20% vs. 15%
| | | | | | | | Viral load: Mean 5.2 log_10_ copies/ml | | | Percent with HIV-1 RNA level of <50 copies/ml at 48 weeks (extension phase): 45% vs. 27% (ITT, p=0.008) | | | Other adverse events ‘similar’ between NFV treatment groups
| | | | | | | | CD4 count: Mean 288 cells/mm^3^
| | | | | | | | Prior AZT (<2 months): 13%
| | | | | | | | History of HIV-related conditions: 62%
Sanne, 2003^488^ | RCT Multicenter | Compare different doses of atazanavir versus NFV in combination therapy | 48 weeks | Viral load 5,000 to 750,000 copies/ml or ≥2,000 copies/ml and CD4 count ≥100 cells/mm^3^, antiretroviral-naïve | Recent opportunistic infection, pregnant or not using effective contraception, significantly abnormal lab tests | Not reported | 15% discontinued | Mean age: 35 years | Primary outcome: Time-averaged change in viral loads | A: d4T 40 mg bid + ddI 400 mg qD + atazanavir 200 mg tid | A vs. B vs. C vs. D | A vs. B vs. C vs. D | A vs. B vs. C vs. D | A vs. B vs. C vs. D | Unrestricted funding from multiple manufacturers | GOOD Blinded to atazanavir dose | II. Run-in period, monotherapy started first, low proportion of patients with AIDS | Trial performed in two stages, efficacy reported from stage 2 and adverse events from both stages (including stage I pilot study)
Protocol 007 | USA | | | | | Not reported | 322 analyzed | Female gender: 36% | Secondary outcomes: Viral load <400 or <50 copies/ml at 48 weeks and changes in CD4 counts | B: d4T 40 mg bid + ddI 400 mg qD + atazanavir 400 mg tid | Percent with viral load <50 copies/ml at 48 weeks: 28% (23/83) vs. 36% (28/78) vs. 42% (33/79) vs. 39% (32/82) (ITT, NS) | Mean increase in CD4 count at week 48: 220 vs. 221. vs. 208 vs. 185 cells/mm^3^ | Death: 2/83 vs. 0/78 vs. 2/79 vs. 1/82 | Withdrawal due to adverse events: 5/102 (5%) vs. 6/101 (6%) vs. 10/107 (9%) vs. 7/100 (7%)
| | | | | | 322 | | Nonwhite race: 44% | | C: d4T 40 mg bid + ddI 400 mg qD + atazanavir 500 mg tid | Percent with viral load < 400 copies/ml at 48 weeks: 61% (51/83) vs. 64% (50/78) vs. 59% (47/79) vs. 56% (46/82) (ITT, NS) | | Clinical progression: not reported | Grade 3–4 adverse event: 11% vs. 26% vs. 26% vs. 20%
| | | | | | | | Mean CD4 count: 348 cells/mm^3^ | | D: d4T 40 mg bid + ddI 400 mg qD + NFV 750 mg tid | | | | Grade 3–4 elevated bilirubin: 20% vs. 41% vs. 49% vs. 1%
| | | | | | | | Mean viral load: 4.73 log_10_ copies/ml
| | | | | | | | Percent with AIDS: 5%
Shafer, 2003^434^ | RCT Multicenter | Compare initial therapy with four-drug regimen to therapy with two sequential three-drug regimens | Mean 2.3 years | HIV-1 RNA >500 copies/ml, prior antiretroviral therapy for <7 days, no serious acute illness or lab abnormalities for 14 days prior to entry | None described | Not reported | 7/987 did not receive medications | Age: Median 36 years | Primary endpoints: failure of two consecutive three-drug regimens or one four-drug regimen, or premature discontinuation of study medication. | A: ddl 400 mg qD (250 mg qD if body weight <60 kg), d4T 40 mg bid (30 mg bid if body weight <60 kg), and EFV 600 mg qD followed by AZT 300 mg bid, 3TC 150 mg bid, and NFV 1250 mg bid | Reached primary endpoint (including discontinuations) A, B, C, or D (three-drug regimens) vs. E or F (four-drug regimens): 272/620 (44%) vs. 169/360 (47%), NS. | Median increase | Deaths | A (n=155) vs. B (155) vs. C (155) vs. D (155) vs. E. (178) vs. F (182) | National Institute of Allergy and Infectious Disease, National Center for Reseach Resources, HIV Clinical Research Program, Universtiy of Alabama at Birmingham | GOOD Blinded to EFV and NFV but not to other antiretrovirals | II. Numbers screened and eligible not reported, CDC stage not reported | Initial therapy with three-drug regimen of AZT, 3TC, and EFV appeared best overall in terms of outcomes and adverse events
| USA and Italy | | | | | Not reported | 980 analyzed | Gender: 18% female | Secondary endpoints: length of time to failure of the initial regimen, time to virologic failure, time to viral suppression, time to severe toxic effect or toxic effect resulting in dose modification, CD4 count at weeks 48, 96, and 144, self-reported level of adherence, and virologic failure accompanied by genotypic drug resistance. | B: ddl 400 mg qD (250 mg qD if body weight <60 kg), d4T 40 mg bid (30 mg bid if body weight <60 kg), and NFV1250 mg bid followed by AZT 300 mg bid, 3TC 150 mg bid, and EFV 600 mg qD | Time to primary endpoint | No significant differences between interventions (median rise 295 cells/mm^3^ at week 144). | A, B, C, or D vs. E or F: 6/620 (1%) vs. 6/360 (2%) | Toxicity associated withdrawals: 21/155 (14%) vs. 20/155 (13%) vs. 11/155 (7%) vs. 6/155 (4%) vs. 23/178 (13%) vs. 12/182 (7%) | Authors were consultants for manufacturers of drugs studies, none were directly employed.
| | | | | | 987 | 263/980 (27%) withdrew (not including those meeting primary endpoints) but analyzed | Non-white: 53% | Assesssed at weeks 4, 8, 12, 16, 20, 24, and every 8 weeks thereafter. | C: AZT 300 mg bid, 3TC 150 mg bid, and EFV 600 mg qD followed by ddl 400 mg qD (250 mg qD if body weight <60 kg), d4T 40 mg bid (30 mg bid if body weight <60 kg), and NFV 1250 mg bid | E vs. B: HR 1.24, 95% CI 0.82, 1.87 | | AIDS-defining events | Pancreatitis: 4.5% vs. 3.9% vs. 0.6% vs. 0.6% vs. 1.1% vs. 0.5% (p=0.005 for A, B, or E vs. C, D, or F) | Role of funder otherwise not described.
| | | | | | | | Viral load: Median 4.9 log_10_ copies/ml | | D: AZT 300 mg bid, 3TC 150 mg bid, and NFV 1250 mg bid followed by ddl 400 mg qD (250 mg qD if body weight <60 kg), d4T 40 mg bid (30 mg bid if body weight <60 kg), and EFV 600 mg qD | F vs. D: HR 1.06, 95% CI 0.71, 1.58 | | 44 in 35 subjects (4%), no significant differences between interventions | Elevated lipase: 15% vs. 13% vs. 8% vs. 6% vs. 11% vs. 8% (p=0.003 for A, B, or E, vs. C, D, or F)
| | | | | | | | CD4 count: Median 278 cells/mm^3^ | | E: ddl 400 mg qD (250 mg qD if body weight <60 kg), d4T 40 mg bid (30 mg bid if body weight <60 kg), EFV 600 mg qD and NFV 1250 mg bid | E vs. A: HR 1.01, 95% CI 0.68, 1.50 | | | Peripheral neuropathy: 26% vs. 19% vs. 6% vs. 10% vs. 24% vs. 9% (p<0.001 for A, B, or E vs. C, D, or F)
| | | | | | | | | | F: AZT 300 mg bid, 3TC 150 mg bid, EFV 600 mg qD and NFV 1250 mg bid | E vs. A: HR 1.01, 95% CI 0.68, 1.50 | | | Rash: 14% vs. 11% vs. 10% vs 10% vs. 11% vs. 13%
| | | | | | | | | | | F vs. C: HR 1.45, 95% CI, 0.94, 2.23 | | | Central nervous system effects: 12% vs. 14% vs. 13% vs. 14% vs. 9% vs. 14%
| | | | | | | | | | | First regimen failure | | | Gastrointestinal effects: 6% vs. 13% vs. 4% vs. 7% vs. 6% vs. 6%
| | | | | | | | | | | E vs. B or D: HR 0.55, 95% CI 0.36, 0.86 | | | Hepatic effects: 8% vs. 10% vs 3% vs. 4% vs. 8% vs. 5% (p=0.004 for A, B, or E vs. C, D, or F)
| | | | | | | | | | | F vs. B or D: HR 0.49, 95% CI 0.30, 0.81 | | | Hematologic effects: 2% vs. 4% vs. 5% vs. 4% vs. 2% vs. 4%
| | | | | | | | | | | E vs. A or C: HR 0.63, 95% CI 0.40, 0.98 | | | Lactic acidosis
| | | | | | | | | | | F vs. A or C: HR 1.21, 95% CI 0.78, 2.20 | | | A, B, or E vs. C, D, or F: 9/488 (1,8%) vs. 0/492
| | | | | | | | | | | First virologic failure
| | | | | | | | | | | E vs. B or D: HR 0.49, 95% CI 0.31, 0.78
| | | | | | | | | | | F vs. B or D: HR 0.41, 95% CI 0.25, 0.68
| | | | | | | | | | | E vs. A or C: HR 0.57, 95% CI 0.35–0.93
| | | | | | | | | | | F vs. A or C: HR 1.16, 95% CI 0.63–2.14
| | | | | | | | | | | Proportion with viral suppression (<50 copies/ml) at 24 weeks
| | | | | | | | | | | F vs. C: 84% vs. 94%
Squires, 2004^489^ | RCT Multicenter | Compare atazanavir to efavirenz in HAART regimens | 48 weeks | Antiretroviral naïve, >16 years old, viral load ≥2,000 copies/ml, CD4 count ≥100 cells/mm^3^ | Suspected primary HIV infection, newly diagnosed opportunistic infection, or any medical condition requiring acute therapy, pregnant or breastfeeding, specified abnormalities in liver tests | Not reported | 805 analyzed | Age: 33 years | Primary outcome: Viral load <400 copies/ml at 48 weeks | A: atazanavir 400 mg qD + AZT 300 mg/3TC 150 mg bid | A vs. B | A vs. B | A vs. B | A vs. B | Funded by Bristol-Myers Squibb, role of funder not reported | GOOD | II. Clinical stage not reported
| North America, South America, Europe, Asia, and South Africa | | | | | 1,046 | 5/810 (0.6%) did not receive study medication | Gender: 35% female | Secondary outcomes: Viral load <50 copies/ml at 48 weeks, changes in viral load and CD4 count, treatment response (2 or more sequential HIV RNA measurements below the limit of quantification) | B: EFV 600 mg qD + AZT 300 mg/3TC 150 mg bid | Percent with HIV-1 RNA level of <400 copies/ml at 48 weeks: 70% (281/404) vs. 64% (258/401) (ITT missing=failure, NS) | Median 455 vs. 446 cells/mm^3^ (NS) | Deaths: 2/404 (0.5%) vs. 3/401 (0.7%) | Withdrawal due to adverse events: 26/404 (6%) vs. 34/401 (8%)
| | | | | | 810 | 144/805 (18%) discontinued prior to week 48 | Non-white race: 67% | | | Percent with HIV-1 RNA level of <50 copies/ml at 48 weeks: 32% (131/404) vs. 37% (150/401) (ITT missing=failure, NS) | | New CDC class C event: 4/404 (1.0%) vs. 4/401 (1.0%) | Withdrawal (overall): 16% vs. 20%
| | | | | | | | Viral load: Median 4.88 log_10_ copies/ml | | | | | | Grade 2–4 adverse events: 41% vs. 45%
| | | | | | | | CD4 count: Median 282 cells/mm^3^ | | | | | | Grade 2–4 rash: 6% vs. 10%
| | | | | | | | | | | | | | Grade 2–4 jaundice: 5% vs. 0%
| | | | | | | | | | | | | | Grade 2–4 dizziness: 2% vs. 6%
| | | | | | | | | | | | | | Grade 3–4 increase in total bilirubin: 33% vs. 0.5%
| | | | | | | | | | | | | | Atazanavir associated with more favorable lipid profile compared to efavirenz arm
Squires, 2000^490^ | RCT Multicenter | Compare two different 3-drug regimens with a protease inhibitor | 48 weeks | >16 years old; laboratory-documented HIV infection; CD4 count ≥200 cells/mm^3^; viral load ≥5,000 copies/ml; ≤28 days prior cumulative treatment with AZT, ddI, d4T, or ddC; no prior 3TC or PI; acceptable laboratory values | AIDS-defining illness requiring treatment within 30 days, requirement for biologic response modifiers, systemic corticosteroids, or investigational agents within 30 days, moderate or severe peripheral neuropathy, diarrhea, or severe malabsorption, inability to tolerate oral medication, history of acute or chronic pancreatitis, hepatitis, or nephrolithiasis, or pregnancy or nursing | Not reported | 204 analyzed | Age: Not reported | Primary outcomes: Viral load <500 copies/ml and <50 copies/ml at 48 weeks | A: d4T 40 mg bid + 3TC 150 mg bid + IDV 800 mg tid | A vs. B | A vs. B | A vs. B | A vs. B | Funding by Bristol-Myers Squibb Company, role of funder not reported | FAIR | II. Number screened and eligible not reported, CDC stage not reported
START I | USA | | | | | Not reported | 2/204 (1%) did not receive study medication | Gender: 23% female | Secondary outcomes: Time to rebound of HIV-1 RNA level (days from initial HIV-1 RNA <500 copies/ml to >500 copies/ml), CD4 counts | B: AZT 200 mg tid (modified to 300 mg bid) + 3TC 150 mg bid + IDV 800 mg tid | Percent with HIV-1 RNA level of <500 copies/ml from 40 to 48 weeks: 55% vs. 48% (ITT, p=0.272), 62% vs. 54% (on-treatment, p=0.213) | Median CD4 cell count increase at week 48: 227 vs. 198 cells/mm^3^ (p=0.385) | Death: 0/101 (0%) vs. 1/103 (1%) | Withdrawal due to adverse events: 5/101 (5%) vs. 6/103 (6%) | | Open-label
| | | | | | 204 | 72/202 (35%) discontinued prior to week 48 | Non-white race: 51% | | | Percent with HIV-1 RNA level of <50 copies/ml at 48 weeks: 49% vs. 47% (ITT, p=0.834), 85 vs. 73% (on-treatment, p=0.107) | Median time-weighted average minus baseline increase in CD4 cell count at week 48: 142 vs. 110 cells/mm^3^ (p=0.033) | Disease progression: 0/101 (0%) vs. 1/103 (1%) | Serious adverse events (requiring hospitalization or considered life-threatening by investigator): overall 19/202 (9%)
| | | | | | | | Viral load: Mean 4.52 log_10_ copies/ml | | | Probability of viral load relapse by week 48: 27% vs. 31% (p=0.597) | | | Nephrolithiasis: 5/101 (5%) vs. 2/103 (2%)
| | | | | | | | CD4 count: Mean 423 cells/mm^3^ | | | | | | Any severe toxicity (grade 3 or 4): 30% vs. 22%
| | | | | | | | | | | | | | Nausea (grade 3 or 4): 3% vs. 7%
| | | | | | | | | | | | | | Diarrhea (grade 3 or 4): 2% vs. 0%
| | | | | | | | | | | | | | Headache (grade 3 or 4): 0% vs. 1%
| | | | | | | | | | | | | | Vomiting (grade 3 or 4): 1% vs. 2%
| | | | | | | | | | | | | | Asthenia (grade 3 or 4): 2% vs. 1%
| | | | | | | | | | | | | | Rash (grade 3 or 4): 1% vs. 0%
| | | | | | | | | | | | | | Paresthesia (grade 3 or 4): 0% vs. 0%
| | | | | | | | | | | | | | Lab abnormality (grade 3 or 4): 35% vs. 25% (p=0.124)
Staszewski, 1999^491^ | RCT Multicenter | Compare EFV + AZT + 3TC vs. IDV + AZT + 3TC vs. EFV + IDV | Median 48 weeks | >13 years old, laboratory evidence of HIV infection, CD4 cell count >50 cells/mm^3^, HIV viral load >10,000 copies/ml, no prior 3TC, NNRTI, or PI | None described | Not reported | 46/450 (10%) | Age: Mean 36 years | Primary endpoint: Suppression of viremia | A: EFV 600 mg qD, AZT 300 mg bid, and 3TC 150 mg bid | A vs. B | A vs. B | A vs. B | A vs. B | Wholly funded by Dupont Pharmaceuticals, role of funder not reported | FAIR | II. Numbers screened and eligible not reported, CDC stage not reported, 15% of patients not antiretroviral naïve | Few clinical events
Study 006 | Europe and North America | | | | | Not reported | 450 | Gender: 14% female | Secondary endpoint: CD4 counts | B: IDV 800 mg tid, AZT 300 mg bid, and 3TC 150 mg bid | Percent with HIV-1 RNA level of <50 copies/ml: 64% vs. 43% (ITT, p<0.05); 90% vs. 79% (ITT, p<0.05) | Mean increase in CD4 counts: 201 vs. 185 cells/mm^3^ | Number of new AIDS-defining illnesses: 7/154 vs. 9/148 (NS) | Withdrawal due to adverse events: 10/154 vs. 30/148 (p<0.001) | | Open-label
| | | | | | 450 | | Non-white: 40% | Weeks 16, 24, 36, and 48 | C: EFV 600 mg qD and IDV 1000 mg tid (results not reported here) | | | | A vs. B
| | | | | | | | Viral load: Mean 58,884 copies/ml | | | | | | Rash: 34% vs. 18% (p<0.05)
| | | | | | | | CD4 count: Mean 345 cells/mm^3^ | | | | | | Dizziness, imparied concentration, insomnia, and abnormal dreaming: 58% vs. 26% (p<0.001)
| | | | | | | | Prior NRTI other than 3TC: 15% | | | | | | Nausea (27%), vomiting (15%), pain (mostly of the flank, 11%), increased bilirubin (8%) significantly higher (by no more than 12, 7, 2, and less than 1 percentage points, respectively) in group C compared to A or B
| | | | | | | | | | | | | | Death: 1 from lymphoma, not considered related to treatment
Staszewski, 2001^492^ | RCT Multicenter | Compare abacavir + 3TC + AZT to IDV + 3TC + AZT | 48 weeks | HIV-seropositive, antiretroviral-naïve, HIV RNA > 10,000 copies/ml, CD4 count > 100 cells/mm^3^, no significant hematologic, liver test, or renal laboratory abnormalities | Previous antiretroviral treatment, HIV vaccine within 90 days, immunomodulatory drugs, radiation therapy, or cytotoxic chemotherapeutic agents within 30 days, pregnant or breastfeeding, clinical pancreatitis or hepatitis, or active HIV-realted illness | 781 screened | 230/562 (41%) did not receive intervention or discontinued study | Age: Median 36 years | Primary endpoint: Suppression of viremia to <400 copies/ml | A: Abacavir 300 mg bid + 3TC 150 mg bid + AZT 300 mg bid | A vs. B | A vs. B | A vs. B | A vs. B | Funding by Glaxo Wellcome, role of funder not reported | GOOD | I. >70% CDC stage A
CNAAB3005 | Australia, North America, and Europe | | | | | 594 eligible | 523 analyzed | Gender: 13% female | Secondary endpoints: Suppression of viremia <50 copies/ml, changes in HIV RNA levels and CD4 counts over 48 weeks, clinical progression, proportion of patients with moderate to severe adverse events, and time to viral rebound | B: IDV 800 mg q8h + 3TC 150 mg bid + AZT 300 mg bid | Percent with HIV-1 RNA level of <400 copies/ml at week 48: 51% vs. 51% (ITT, NS), 86% vs. 94% (as-treated, NS) | Median increase in CD4 count area under the curve minus baseline: 107 × 106/L vs. 93 × 106/L (NS) | New AIDS-defining illness: 3/262 vs. 1/265 | Withdrawal due to adverse events: 45/262 (17%) vs. 58/265 (22%)
| | | | | | 562 enrolled | | Non-white: 27% | Assessed every 2 weeks for the first 4 weeks, then every 4 weeks through week 48 | | Percent with HIV-1 RNA level of <50 copies/ml at week 48: 40% vs. 46% (ITT, NS), 69% vs. 82% (as-treated, NS) | | Deaths: 4 total not associated with HIV-related disease progression | Deaths: 3/262 (1 abacavir hypersensitivity, 2 cardiovascular) vs. 1/265 (drug overdose)
| | | | | | | | Viral load: Median 4.83 log_10_ copies/ml | | | | | | Possible abacavir hypersensitivity: 19/262 (7%) vs. 6/265 (2%)
| | | | | | | | CD4 count: Median 360 cells/mm^3^ | | | | | | Serious events: 21% vs. 22%
| | | | | | | | | | | | | | Severe laboratory abnormalities: 16% vs. 19%
| | | | | | | | | | | | | | Nausea (grade 2 to 4): 16% vs. 14%
| | | | | | | | | | | | | | Nausea and vomiting (grade 2 to 4): 8% vs. 8%
| | | | | | | | | | | | | | Malaise and fatigue (grade 2 to 4): 10% vs. 10%
| | | | | | | | | | | | | | Headache (grade 2 to 4): 10% vs. 5%
| | | | | | | | | | | | | | Renal signs and symptoms (grade 2 to 4): <1% vs. 5%)
van Leeuwen, 2003^493^ | RCT Multicenter | Compare D4T + ddI + either IDV or NVP or 3TC | 96 weeks | Antiretroviral-naïve, HIV-1 infection, asymptomatic (CDC class A), plasma HIV-1 RNA ≥500 copies/ml, negative pregnancy test within one month if female | Breastfeeding, significantly abnormal hematologic, liver test, or renal function test; history of neuropathy, nephrolithiasis, or pancreatitis; radiotherapy or chemotherapy in the month prior to treatment, severe non-HIV-related disease | Not reported | 15/298 (5%) did not receive intervention | Age: Mean 36 years | Primary endpoints: Suppression of viremia to <500 copies/ml at week 48 (ITT) and at week 96 | A: d4T 40 mg bid (30 mg bid if body weight <60 kg) + ddI 400 mg qD (250 mg qD if body weight <60 kg) + IDV 800 mg tid | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | Funding by Bristol-Myers Squibb, Merck, and Boehringer Ingelheim GmbH, role of funders not reported | FAIR | I. >90% CDC stage A
Atlantic | North America and Europe | | | | | Not reported | 283 analyzed | Gender: 20% female | Secondary endpoints: Suppression of viremia <500 copies/ml at week 96, change in CD4 counts, adverse events | B: d4T 40 mg bid (30 mg bid if body weight <60 kg) + ddI 400 mg qD (250 mg qD if body weight <60 kg) + NVP 400 mg qD (after initial dosing scheme of 200 mg qD for first 2 weeks) | Percent with HIV-1 RNA level of <500 copies/ml at week 48: 57% vs 58% vs. 59% (ITT, p=0.965), 82% vs. 89% vs. 81% (on-treatment, p=0.390) | Mean increase in CD4 count at week 96: 238 vs. 139 vs. 233 cells/mm^3^ (p=0.13) | Death: 0% vs. 0% vs. 1/109 (1%) | Withdrawal due to adverse event prior to week 96: 12% vs. 7% vs. 9% | | Open-label
| | | | | | 298 enrolled | 100/298 (34%) discontinued study by week 48 | Non-white race: Not reported | Assessed at weeks 0, 2, 6, 12 and every 12 weeks thereafter | C: d4T 40 mg bid (30 mg bid if body weight <60 kg) + ddI 400 mg qD (250 mg qD if body weight <60 kg) + 3TC 150 mg bid | Percent with HIV-1 RNA level of <50 copies/ml at week 48: 55% vs. 54% vs. 46% (ITT, p=0.353), 80% vs. 81% vs. 59% (on-treatment, p=0.004) | | Progression to CDC stage C: 1/100 (1%) vs. 1/89 (1%) vs. 1/109 (1%) | Any grade 3 or 4 adverse event: 19% vs. 13% vs. 11%
| | | | | | | 159/298 (53%) discontinued study by week 96 | Viral load: Median 4.25 log_10_ copies/ml | | | Percent with HIV-1 RNA level of <500 copies/ml at week 96: 50% vs. 60% vs. 45% (ITT, p=0.120), 87% vs. 86% vs. 79% (on-treatment, p=0.491) | | | Dermatologic adverse event (grade 3 or 4): 0% vs. 7% vs. 0%
| | | | | | | | CD4 count: Median 406 cells/mm^3^ | | | Percent with HIV-1 RNA level of <50 copies/ml at week 96: 44% vs. 55% vs. 28% (ITT, p<0.001), 79% vs. 82% vs. 51% (on-treatment, p=0.001) | | | Elevated transaminases (grade 3 or 4): 4% vs. 9% vs. 9%
| | | | | | | | CDC stage A: 92% | | | | | | Elevated bilirubin (grade 3 or 4): 21/94 (22%) vs. 0% vs. 6/104 (6%)
| | | | | | | | | | | | | | Elevated GGT (grade 3 or 4): 6/94 (6%) vs. 18/85 (21%) vs. 8/104 (8%)
| | | | | | | | | | | | | | Mean percentage increase in LDL: 14% vs. 19% vs. 3% (NS)
| | | | | | | | | | | | | | Mean percentage increase in HDL: 6% vs. 40% vs. 20% (p<0.001 for NVP vs. IDV)
van Leth, 2004^431^ | RCT Multicenter | Compare HAART regimens using different NNRTIs alone or in combination with 2 NRTIs | 48 weeks | Antiretroviral naïve, chronic HIV Infection, viral load >5,000 copies/ml | Pregnancy or lactation, significant laboratory abnormalities (hematologic, kidney function, lipase, liver tests), pancreatitis or neuropathy, dialysis, radiotherapy, cytotoxic, or immunomodulating therapy, HIV-2 infection, likely nonadherence | 1,432 screened | 1216 analyzed | Mean age: 33–34 years | Primary outcome: Treatment failure (virologic, disease progression, or therapy change | A: NVP 400 mg qD + d4T 40 mg bid + 3TC 150 mg bid | A vs. B vs. C vs. D | A vs. B vs. C vs. D | A vs. B vs. C vs. D | A vs. B vs. C vs. D | Boehringer-Ingelheim, had input into study design and analyses, but had no influence on reporting of the data or decision to publish | FAIR | I. Relatively few patients CDC stage C | Higher rate of laboratory adverse events in patients with HBV or HCV (7.7% and 9.1% of study population). Intervention B added to protocol later; analyses showed no differences before adding 4th arm and after.
2NN | Europe, North and South America, Thailand, Australia, and South Africa | | | | | 1,216 eligible | 301/1,216 (25%) withdrew or did not complete original intervention | Female gender: 32–39% | Secondary outcomes: Virologic failure, proportion of patients with viral load <50 copies/ml, change in CD4 count, adverse events | B: NVP 200 mg bid + d4T 40 mg bid + 3TC 150 mg bid | Treatment failure (virologic, clinical progression, or therapy change) by week 48: 96/220 (44%) vs. 169/387 (44%) vs. 151/400 (38%) vs. 111/209 (53%) | Median increase in CD4 count at week 48: 170 vs. 160 vs. 160 vs. 150 cells/mm^3^ (p=0.8) | Death: 7/220 (3.2%) vs. 9/387 (2.3%) vs. 7/400 (1.8%) vs. 2/209 (1.0%) | Change in treatment: 64/220 (29%) vs. 85/387 (22%) vs. 80/400 (20%) vs. 72/209 (34%); (p<0.0002 overall; p=0.050 for A vs. B, p<0.0001 for C vs. D) | | Open-label
| | | | | | 1,216 enrolled | | Race: Not reported | | C: EFV 600 mg qD + d4T 40 mg bid + 3TC 150 mg bid | Virological failure (decline of less than 1 log_10_ within the first 12 weeks or 2 consecutive measurements >=50 copies/ml from week 24 onwards or viral load >=50 copies/ml at week 48): 25/96 (11.4%) vs. 73/169 (18.9%) vs. 61/151 (15.3%) vs. 34/111 (16.3%) (p=0.016 for A vs. B, otherwise NS) | | Clinical progression: 7/220 (3.2%) vs. 11/387 (2.8%) vs. 10/400 (2.5%) vs. 5/209 (2.4%) | Temporary or premanent discontinuation of study drug due to adverse event or HIV event: 53/220 (24%) vs. 83/387 (22%) vs. 63/400 (16%) vs. 63/209 (30%)
| | | | | | | | CDC stage C: 19–22% | | D: NVP 400 mg qD + EFV 800 mg qD + d4T 40 mg bid + 3TC 150 mg bid | Percent with HIV-1 RNA level <50 copies/ml at 48 weeks: 154/220 (70.0%) vs. 253/387 (65.4%) vs. 280/400 (70.0%) vs. 131/209 (62.7%) (p=0.193 overall, NS for between-intervention comparisons) | | | At least one grade 3 or 4 clinical adverse event: 15.0% vs. 20.4% vs. 18.0% vs. 24.4% (p=0.014 for A vs. D, otherwise NS)
| | | | | | | | Median CD4: 190–200 cells/mm^3^ | | | | | | At least one grade 3 or 4 laboratory toxicity: 13.6% vs. 8.3% vs. 4.5% vs. 9.1% (p=0.001 overall; p<0.001 for A vs. C)
| | | | | | | | Median viral load: 4.7 log_10_ copies/ml
Walmsley, 2002^494^ | RCT Multicenter | Compare lopinavir-RTV + d4T + 3TC vs. NFV + d4T + 3TC | 48 weeks | >12 years old, no prior d4T or 3TC or prior antiretroviral therapy for >14 days, no recent opportunistic infections | Pregnancy, elevated liver tests | 859 screened | 33 patients didn't receive study drug | Age: Mean 38 years | Primary outcomes: Viral load <400 copies/ml at 24 weeks and time to loss of virologic response through 48 weeks | A: Lopinavir 400 mg/RTV 100 mg bid + d4T 40 mg bid + 3TC 150 mg bid | A vs. B vs. C | A vs. B | A vs. B | A vs. B | Funding by Abbott Laboratories. Role of funder not reported | GOOD | I. High proportion of patients screened for trial enrolled | A vs. B
M98–863 | North America, South America, Europe, Africa, and Australia | | | | | 686 eligible | 653 analyzed | Gender: 20% female | Secondary outcomes: Viral load <50 copies/ml at 24 and 48 weeks and changes in CD4 count, adverse events | B: NFV 750 mg tid + d4T 40 mg bid + 3TC 150 mg bid | Percent with HIV-1 RNA level of <400 copies/ml at week 24: 79% vs. 71% (p<0.05) | Mean increase in CD4 count: 207 vs. 195 cells/mm^3^ | Death: 5/326 (1.5%) vs. 3/327 (0.9%) | Withdrawal due to adverse events: 11/326 (3.4%) vs. 12/327 (3.7%) | | | | Resistance mutation in HIV protease in patients with >400 copies/ml HIV RNA: 0/37 (0%) vs. 25/76 (33%)
| | | | | | 686 enrolled | 133/653 (20%) discontinued study | Non-white race: 43% | | | Percent with HIV-1 RNA level of <50 copies/ml at week 48: 67% vs. 52% (p<0.001) | | | Abdominal pain: 4% vs. 3%
| | | | | | | | Viral load: Mean 4.9 log_10_ copies/ml | | | Persistent response through week 48: 84% vs. 66% (HR 2.0, 95% CI 1.5 to 2.7) | | | Asthenia: 4% vs. 3%
| | | | | | | | CD4 count: Mean 259 cells/mm^3^ | | | | | | Headache: 2.5% vs. 1.8%
| | | | | | | | | | | | | | Diarrhea: 16% vs. 17%
| | | | | | | | | | | | | | Dyspepsia: 2.1% vs. 0.3% (p<0.05)
| | | | | | | | | | | | | | Nausea: 7% vs. 5%
| | | | | | | | | | | | | | Vomiting: 2.5% vs. 2.4%
| | | | | | | | | | | | | | AST or ALT >5 times upper limit of normal: 4% vs. 5%
| | | | | | | | | | | | | | Total cholesterol >300 mg/dL: 9% vs. 5%
| | | | | | | | | | | | | | Triglycerides >750 mg/dL: 9% vs. 1% (p<0.001)

Evidence Table 2. Studies Evaluating Clinical Efficacy of Pneumococcal and Influenza Vaccination in Patients with Chronic HIV Infection

Author, year | Type of study/ Setting | Sample size | Main findings | Internal validity
Pneumococcal vaccination
French, 2000^550^ | RCT | 1392 | Vaccinated vs. non-vaccinated | GOOD
| Uganda | | First invasive pneumococcal disease: 15/697 (2.2%) vs. 10/695 (1.4%) [HR 1.47; 95% CI 0.7–3.3]
| | | All pneumococcal events: 20/697 (2.9%) vs. 14/695 (3.0%) [HR 1.41; 95% CI 0.7–2.8]
| | | All-cause pneumonia: 40/697 (5.7%) vs. 21/695 (3.0%) [HR 1.89; 95% CI 1.1–3.2]
| | | Death: 176/697 (25%) vs. 174/695 (25%) [HR 1.08; 95% CI 0.87–1.33]
Dworkin, 2001^540^ | Cohort | 39086 | Non-vaccinated vs. vaccinated and CD4 count <200 vs. vaccinated and CD4 count 200–499 vs. vaccinated and CD4 count >=500 | GOOD
| USA | | Episodes of pneumococcal disease episodes/patient years (1000 patient years): 399/43100 (9.3) (referent) vs. 79/7895 (10.0) (p=0.99) vs. 64/10843 (5.9) (p=0.85) vs. 16/6206 (2.6) (p=0.02)
| | | Vaccine efficacy in patients with CD4 cell count >=500: Adjusted RR 0.5 (p=0.05)
Lindenburg, 2001^552^ | Cohort | 48 | Non-vaccinated vs. vaccinated | GOOD
| The Netherlands | | Incidence of all-cause pneumonia (100 patient-years): 51/352 (14.5) vs. 14/71 (19.75) [Adjusted RR 1.01; 95% CI 0.53–1.91]
Breiman, 2000^554^ | Case-control | 176 cases and 327 matched controls | Cases (hospitalized for invasive pneumococcal infection) vs. controls | GOOD
| USA | | Proportion: 41/162 (25%) vs. 112/305 (93%) [OR 0.59; 95% CI 0.38–0.91]
| | | Vaccine efficacy
| | | Adjusted for all variables: 49% (95% CI 12–70%); p=0.02
Guerrero, 1999^555^ | Nested case-control | 127 cases and 127 matched controls | Cases (all-cause pneumonia) vs. controls | GOOD
| USA | | Proportion vaccinated: 70/127 (55%) vs. 99/127 (78%); p<0.01
| | | Vaccine efficacy
| | | Overall adjusted odds ratio: 0.31 (95% CI 0.16–0.62); p<0.0001
| | | Stratified by CD4 count
| | | CD4 <100: 0.36 (0.16–0.84); p=0.02
| | | CD4 100–199: 0.23 (0.08–0.67); p<0.01
| | | CD4 >200: 0.22 (0.09–0.54); p<0.001
Gebo, 1996^553^ | Nested case-control | 85 cases and 85 matched controls | Cases (acute febrile illness and culture positive for Streptococcus pneumoniae) vs. controls | GOOD
| USA | | Proportion vaccinated
| | | Overall: 35/85 (41%) vs. 32/85 (37%); p=0.70
| | | CD4>200 cells/mm3: 6/85 (7%) vs. 23/85 (27%); p=0.01
| | | CD4<=200 cells/mm3: 24/85 (28%) vs. 8/85 (9%); p=0.01
| | | Risk of pneumococcal disease:
| | | Pneumococcal vaccine and CD4>200: AOR 0.22 (0.05–0.98); p=0.05
Influenza vaccination
Tasker, 1999^568^ | RCT | 102 (46 asymptomatic) | Vaccinated vs. non-vaccinated: | GOOD
| USA | | Respiratory illness: 16/55 (29%) vs. 23/47 (49%); p=0.04
| | | Symptomatic, laboratory-confirmed influenza: 0/55 (0%) vs. 10/47 (21%) (protective efficacy 100% [95% CI, 73% to 100%])

Evidence Table 3. Systematic Reviews on The Efficacy of Different Regimens for PCP Prophylaxis

Author, year | Purpose of study | Number of studies/Date of searches | Number of patients | Results | Adverse events | Quality rating | Comments
Bucher, 1997^596^ | Compare different regimens for P carinii prophylaxis | 22 | 4832 received TMP/SMX (1484), dapsone (1548), or aerosolized pentamidine (1800) | P carinii pneumonia: (RR) | Drug-limiting toxicity: RR | GOOD | In 100 patients, TMP/SMX rather than AP will prevent 3–7 cases of PCP and 0–3 cases of toxoplasma and delay death in 0–9 patients at cost of 21 patients experiencing toxicity.
| | Not reported | | Dapsone/pyrimethamine vs. AP: 0.90 (0.71–1.15) | Dapsone/pyrimethamine vs. AP (trials including subjects with CD4 count >=100): 4.84 (2.36–9.92) | | In 100 patients, TMP/SMX rather than dapsone/pyrimethamine will prevent 1–8 cases of PCP, equivalent results in terms of toxoplamsa encephalitis and death, and slightly higher rate of drug-limiting toxicity.
| | | | TMP/SMX vs. AP: 0.59 (0.45–0.76) | TMP/SMX vs. AP (trials including subjects with CD4 count >=100): 5.86 (3.88–8.84) | | 4/22 studies secondary prophylaxis only, 5/22 primary and secondary prophylaxis, 13/22 primary prophylaxis only.
| | | | TMP/SMX vs. dapsone/pyrimethamine: 0.49 (0.26–0.92) | Dapsone/pyrimethamine vs. AP (trials including subjects with CD4 count <100): 1.66 (1.10–2.57)
| | | | Toxoplasma encephalitis: | TMP/SMX vs. AP (trials including subject with CD4 count <100): 2.69 (0.99–7.29)
| | | | Dapsone/pyrimethamine vs. AP: 0.72 (0.54–0.97) | TMP/SMX (low-dose) vs. AP: 2.99 (1.14–7.89)
| | | | TMP/SMX vs. AP: 0.78 (0.55–1.11) | TMP/SMX (high-dose) vs. AP: 4.92 (2.68–9.07)
| | | | TMP/SMX (one DS tablet thrice weekly or one SS tablet daily) vs. AP: 0.41 (0.19–0.90) | TMP/SMX (low-dose) vs. TMP/SMX (high-dose): p=0.39
| | | | TMP/SMX (one DS tablet daily) vs. AP: 0.54 (0.36–0.80); p=0.54 for difference between subgroups of trials | TMP/SMX vs. dapsone/pyrimethamine: 1.08 (0.88–1.25)
| | | | TMP/SMX vs. dapsone/pyrimethamine: 1.17 (0.68–2.18)
| | | | Death:
| | | | Dapsone/pyrimethamine vs. AP: 1.07 (0.90–1.27)
| | | | TMP/SMX vs. AP: 0.88 (0.74–1.06)
| | | | TMP/SMX vs. dapsone/pyrimethamine: 1.08 (0.88–1.25)
Ioannidis, 1996^597^ | Compare different regimens for P carinii prophylaxis | 35 | 6583 | Pneumocystis events: (RR) | Rate of treatment-limiting toxic events (per 100 pt years): 19 (18–21) for TMP/SMX vs. 15 (95% CI, 14 to 17) for dapsone-based regimens | GOOD
| | Not reported | | Any primary prophylaxis vs. placebo: 0.39 (0.27–0.55) | Total withdrawals (per 100 person-years): 31 (29 to 34) vs. 28 (26–31)
| | | | Oral regimens vs. AP: 0.73 (0.59–0.91) | Discontinuation of prophylaxis because of severe side effects:
| | | | TMP/SMX vs. AP: 0.58 (0.45–0.75) | Any oral regimen vs. AP: 5.38 (3.69–7.83)
| | | | DBR vs. AP: 0.93 (0.72–1.19) | TMP/SMX vs. AP: 7.16 (5.21–9.83)
| | | | TMP/SMX vs. DBR: 0.61 (0.34–1.10) | DBR vs. AP: 4.26 (2.18–8.33)
| | | | PCP-related deaths: | TMP/SMX vs. DBR: 1.30 (1.04–1.62)
| | | | Any primary prophylaxis vs. placebo: 0.37 (0.10–1.34) | Adjusted odds ratio estimates for discontinuing TMP/SMX because of side effects: 0.57 (0.46–0.70) for 1 DS tab 3 times/wk (14.5%) vs. 1 DS tab/day (23.2%)
| | | | Oral regimens vs. AP: 0.63 (0.25–1.61)
| | | | TMP/SMX vs. AP: 1.20 (0.29–4.88)
| | | | DBR vs. AP: 0.54 (0.18–1.60)
| | | | TMP/SMX vs. DBR: 0.73 (0.16–3.31)
| | | | All deaths:
| | | | Any primary prophylaxis vs. placebo: 0.87 (0.60–1.25)
| | | | Oral regimens vs. AP: 0.84 (0.33–2.11)
| | | | TMP/SMX vs. AP: 0.99 (0.80–1.22)
| | | | DBR vs. AP: 0.98 (0.86–1.12)
| | | | TMP/SMX vs. DBR: 0.95 (0.82–1.11)
| | | | Failure rates (per 100 person-years) according to TMP/SMX dose:
| | | | 5.9 (4.4 to 7.7) with two DS tabs/day vs. 0.5 (0–2.9) with one DS tab/day vs. 1.8 (1 to 3.3) with one DS tab 3 times/wk or one single-strength tab/day

TMP/SMX Trimethoprim/sulfamethoxazole

AP Aerosolized Pentamidine

DBR Dapsone-based regimen

DS Double strength

PCP P. carinii pneumonia

Evidence Table 4. Trials of Primary PCP and Toxoplasmosis Prophylaxis Not Included in Systematic Reviews

Author, year | Type of study/Setting | Aims | Duration of follow-up | Main eligibility criteria | Enrolled | Demographics / Baseline disease | Interventions | Clinical outcomes | Adverse events | Funding source | Internal validity rating | Relevance to screening | Comments
Murri, 2001^599^ | RCT | Evaluate effectiveness of dapsone and TMP/SMX in preventing bacterial infections | Median 592 days | HIV infection, CD4 count <200 cells/mm^3^, no previous PCP or TE, no intolerance to study drugs | 244 | Mean age: 37 years | A: TMP/SMX DS 1 tablet qD | B vs. A: RR | Not reported | Not reported | GOOD | II. Low proportion of CDC stage A | Secondary outcome of study designed to evaluated comparative effectiveness of regimens for prophylaxis.
| Italy | | | | | Female gender: 74% | B: Dapsone 50–100 mg qD + | Bacteremia: 1.3 (0.78–2.09)
| | | | | | CD4 count ≤100 cells/mm^3^ (%): 45% | pyrimethamine 50 mg qweek + | Pneumonia: 1.2 (0.54–2.87)
| | | | | | CDC stage A: 36% | leucovorin 25 mg qweek | Sinusitis/otitis: 1.1 (0.59–2.09)
| | | | | | Antiretroviral therapy: 52% | | 2 year-probablity of remaining infection-free
| | | | | | | | Bacteremia: 0.92 (0.82–0.96) vs. 0.88 (0.76–0.94)
| | | | | | | | Pneumonia: 0.70 (0.58–0.79) vs. 0.63 (0.81–0.97)
| | | | | | | | Sinusitis/otitis: 0.83 (0.73–0.89) vs. 0.82 (0.72–0.88)
Dunne, 1999^604^ | RCT | Evaluate effectiveness of azithromycin in addition to standard PCP prophylaxis (secondary outcome) | Mean 318 days | >17 years old, HIV-1 seropositive, CD4 count <100 cells/mm^3^, no active opportunistic disease, no hypersensitivity to study drugs, and expected survival >6 months | 508 without prior PCP | Mean age: 38 years | A: Rifabutin 300 mg qD | B or C vs. A | A vs. B vs. C | California Collaborative Treatment Group, Pfizer, Adria Laboratories | GOOD | I.
| USA | | | | | Female gender: 5% | B: Azithromycin 1200 mg qweek | Risk for developing PCP: Adjusted RR 0.42 (0.24–0.76), p=0.004 | Any adverse event: 76% vs. 88% vs. 90%
| | | | | | Median CD4 count: 40 cells/mm^3^ | C: Rifabutin + azithromycin | Risk for developing PCP among those receiving >30 days of TMP/SMX or dapsone (per 100 patient-years): 4.5 vs. 8.5 | Discontinuation due to adverse event: 16% vs. 14% vs. 23%
| | | | | | Previous PCP: 27% | | Risk for developing PCP among those receiving <30 days of TMP/SMX or dapsone (per 100 patient-years): 11.0 vs. 60.9 (HR 0.23 [0.07–0.75], p=0.014)
| | | | | | TMP/SMX: 59%
| | | | | | Dapsone: 19%
| | | | | | Pentamidine: 17%
El-Sadr, 1998^602^ | RCT | Compare atovaquone and dapsone for PCP prophylaxis in patients intolerant to trimethoprim or sulfonamides | Median 27 months | >13 years old, HIV-1 infected, CD4 count <200 cells/mm^3^, treatment-limiting reaction to trimethoprim or sulfonamides and adequate glucose-6-phosphate dehydrogenase levels | 759 without prior PCP | Mean age: 38 years | A: Atovaquone 1500 mg qD | A vs. B | A vs. B | Community Program for Clnical Research on AIDS and the AIDS Clinical Trials Group, General Clinical Research Center Units, Glaxo (provided atovaquone) and Jacobus Pharmaceuticals (provided dapsone) | GOOD | II. Patients already failed trimethoprim-sulfamethoxazole
| USA | | | | | Female gender: 12% | B: Dapsone 100 mg qD (also encouraged to take pyrimethamine 50 mg and leucovorin 15 mg each week) | PCP (per 100 person-years): 11.3 vs. 14.1 (RR 0.81 [0.58–1.12], p=0.20) | Discontinuation: 81% vs. 78%
| | | | | | Median CD4 count: 55 vs. 65 cells/mm^3^ | | Death (per 100 person-years): 23.2 vs. 18.6 (RR 1.25 [0.98–1.59], p=0.07) | Discontinuation (due to adverse event): 28% vs. 29%
| | | | | | Non-white race: 35% | | Toxoplasmosis: RR 1.18 (0.26–5.30), p=0.83
| | | | | | On dapsone at randomization: 52%
El-Sadr, 1999^600^ | RCT | Compare daily and thrice weekly TMP/SFX for PCP prophylaxis | Median 22 months | >13 years old, HIV-1 infected, CD4 count <200 cells/mm^3^ | 2212 without prior PCP | Mean age: 39 years | A: Trimethoprim-sulfamethoxazole 1 double-strength tab daily | A vs. B | A vs. B | National Institute of Allergy and Infectious Diseases; Glaxo provided Septra | GOOD | II. High proportion on intervention prior to enrollment
| USA | | | | | Female gender: 16% | B: Trimethoprim-sulfamethoxazole 1 double-strength tab 3 times weekly | PCP (per 100 person-years): 3.3 vs. 3.8 (Adjusted RR 0.84 [0.62–1.15], p=0.28) | Any adverse event requiring discontinuation (per 100 person-years): 13.9 vs. 6.3 (Adjusted RR 2.14 [1.73–2.66], p<0.001)
| | | | | | Non-white race: 62% | | Death (per 100 person-years): 18.9 vs. 18.5 (Adjusted RR 0.96 [0.84–1.10], p=0.59)
| | | | | | Mean CD4 count: 132 cells/mm^3^ | | PCP or death (per 100 person-years): 20.7 vs. 20.5 (Adjusted RR 0.95 [0.84–1.08], p=0.47)
| | | | | | On TMP/SFX at randomization: 70% | | Toxoplasmosis (per 100 person-years): 1.8 vs. 1.8 (Adjusted RR 1.02 [0.39–2.63], p=0.97)
| | | | | | On antiretroviral: 34%
Payen, 1997^603^ | RCT | Compare dapsone and pyrimethamine-sulfadoxine for PCP prophylaxis | Mean 533 days | HIV positive, CD4 count <200 cells/mm^3^, no prior PCP or cerebral toxoplasmosis | 209 | Mean age: 36 years | A: Dapsone 100 mg qD | A vs. B | A vs. B | Not reported | GOOD | II. Low proportion of CDC stage A
| Belgium | | | | | Female gender: 30% | B: Pyrimethamine 25 mg/sulfadoxine 500 mg qweek | PCP (per 100 person-years): 7.1 vs. 8.2 (p=0.374) | Any adverse events: 14/96 (14.5%) vs. 16/97 (16.5%) (p=0.87)
| | | | | | Non-white race: 24% | | Death: 25/96 (26%) vs. 22/97 (22%) (p=0.472) | Adverse event requiring discontinuation: 10/96 (10%) vs. 9/97 (9%)
| | | | | | Mean CD4 count: 140 cells/mm^3^ | | Cerebral toxoplasmosis (per 100 person-years): 4.9 vs. 4.6 (p=0.494)
| | | | | | CDC category A: 28%
Schneider, 1995^601^ | RCT | Compare two doses of TMP/SMX for PCP prophylaxis | Median follow-up 409 days and 299 days in low-dose and high-dose groups, respectively | HIV positive, CD4 count <200 cells/mm^3^, Karnofsky score >=60, >=16 years old | 260 | Mean age: 37 years | A: TMP/SMX SS 1 tablet qD | A vs. B | A vs. B | Dutch Ministry of Health, Rhone-Poulenc Pharma | FAIR. Open-label | II. Proportion of asymptomatic patients unclear
| The Netherlands and Denmark | | | | | Female gender: 7% | B: TMP/SMX DS 1 tablet qD | PCP: 0 vs. 0 | Any adverse events at 1 year: 18% vs. 31% (HR 2.0, CI 1.2–3.3)
| | | | | | Race: Not reported | | Death at 1 year: 20/131 (15%) vs. 15/129 (12%) (HR=0.9, CI 0.5–1.6) | Withdrawal (all-cause): 22/131 (17%) vs. 21/129 (16%)
| | | | | | CDC stage II: 26% | | Cerebral toxoplasmosis: 2/131 (1.5%) vs. 1/129 (0.7%)
| | | | | | Mean CD4 count: 93 cells/mm^3^
| | | | | | AZT use: 51%

TMP/SMX Trimethoprim/sulfamethoxazole

PCP P. carinii pneumonia

SS Single strength

DS Double strength

AZT Zidovudine

Evidence Table 5. Systematic Reviews on The Efficacy of Tuberculosis Prophylaxis

Author, year | Purpose of study | Number of studies/ Date of searches | Number of patients | Results | Adverse events | Quality rating | Comments
Wilkinson | Assess the effects of preventive therapy with anti-tuberculosis drugs in people with HIV infection | 7 trials | 3001 receiving treatment and 1651 controls | Incidence of active disease | Discontinued therapy due to adverse event | GOOD | Follow-up limited to 15–33 months. In patients with a positive skin test, 19 people would need to be treated to prevent 1 case of tuberculosis and 28 to prevent 1 death with a 3–12 month course of intervention.
Most recent update 2002 | | 1980-2000 | | Active drug vs. placebo (5 trials): 77/3001 vs. 88/1651, OR 0.54 (0.39–0.76) | Any drug vs. placebo: 102/2871 vs. 51/1973; OR 1.75 (1.23–2.47)
Most recent substantive update 2000^606^ | | | | Active drugs vs. placebo in patients with positive tuberculin skin test (4 trials): 28/1746 vs. 46/615; OR 0.24 (0.14–0.40) | Isoniazid vs. rifampicin plus pyrazinamide: 55/1351 vs. 84/1374; OR 0.64 (0.45–0.91)
| | | | Active drugs vs. placebo in patients with negative skin test (5 trials): 44/1215 vs. 40/987; OR 0.87 (0.56–1.36)
| | | | Isoniazid vs. placebo in patients with positive skin test (4 trials): 18/689 vs. 48/615; OR 0.35 (0.21–0.59)
| | | | Rifampicin plus isoniazid vs. placebo in patients with positive skin test (1 trial): 9/556 vs. 21/464; OR 0.36 (0.17–0.75)
| | | | Isoniazid plus rifampicin plus pyrazinamide vs. placebo in patients with positive skin test (1 trial): 10/462 vs. 21/464; OR 0.48 (0.24–0.99)
| | | | Isoniazid vs. rifampicin + pyrazinamide (3 trials): 49/1351 vs. 50/1374; OR 1.00 (0.67–1.50)
| | | | Death
| | | | Active drug vs. placebo (5 trials): 529/3001 vs. 362/1651; OR 0.96 (0.82–1.13)
| | | | Active drug vs. placebo in patients with positive skin test: 194/1746 vs. 94/615; OR 0.77 (0.58–1.03)
| | | | Active drug vs. placebo in patients with negative skin test: 326/1215 vs. 267/987; OR 1.07 (0.88–1.30)
| | | | Isoniazid vs. placebo in patients with positive skin test (4 trials): 70/689 vs. 84/615; OR 0.70 (0.50–0.98)
| | | | Rifampicin plus isoniazid vs. placebo in patients with positive skin test (1 trial): 57/556 vs. 64/464; OR 0.71 (0.49–1.04)
| | | | Isoniazid plus rifampicin plus pyrazinamide vs. placebo in patients with positive skin test (1 trial): 58/462 vs. 64/464; OR 0.90 (0.61–1.31)
| | | | Isoniazid vs. rifampicin + pyrazinamide (3 trials): 264/1351 vs. 251/1374; OR 1.09 (0.90–1.32)
Bucher,1999^605^ | Assess the effects of preventive therapy with isoniazid in people with HIV infection | 7 trials | 2367 received intervention and 2162 controls | Incidence of TB | Any adverse event | GOOD | Incidence of TB in patients with positive skin test (per 100 patient-years): 3.4–10.0; number of patients treated with INH to prevent one case of TB 24–70.
| | 1985-1997 | | INH vs. placebo (7 trials): RR 0.58 (0.43–0.80) | INH vs. placebo (4 trials with more detailed adverse event data): RR 1.36 (1.00–1.86), p=0.27
| | | | INH vs. placebo in patients with positive skin test (5 trials): RR 0.40 (0.24–0.65) | Drug-limiting toxicity
| | | | INH vs. placebo in patients with negative skin test (5 trials): RR 0.84 (0.54–1.30) | INH vs. placebo (4 trials): RR 1.66 (0.83–3.32), p=0.18
| | | | Death | Serum AST level >2 × ULN
| | | | INH vs. placebo (7 trials): RR 0.94 (0.83–1.07) | INH vs. placebo (4 trials): RR 1.80 (1.05–3.10), p=0.11
| | | | INH vs. placebo in patients with positive skin test (5 trials): RR 0.79 (0.37–1.70)
| | | | INH vs. placebo in patients with negative skin test (5 trials): RR 1.02 (0.90–1.17)

TB Tuberculosis

INH Isoniazid

AST Aspartate Transaminase

ULN Upper limit of normal

Evidence Table 6. Trials of Primary MAC Prophylaxis

Author, year | Type of study/Setting | Aims | Duration of follow-up | Main eligibility criteria | Enrolled | Demographics / Baseline disease | Interventions | Clinical outcomes | Adverse events | Funding source | Internal validity rating | Relevance to screening | Comments
Benson, 2000^611^ | RCT | Compare clarithromycin or rifabutin alone or in combination for MAC prophylaxis | Median 574–595 days | ≥12 years old, HIV-infection, CD4 count ≤100 cells/mm^3^, 2 blood cultures negative for MAC, no signs of symptoms of MAC disease, and Kar50 | 1216 enrolled and 1178 randomized | Median age: 38 years | A: Clarithromycin 500 mg bid | A vs. B vs. C | A vs. B. vs. C | Adults AIDS Clinical Trials Group and the Terry Beirn Community Programs for Clinical Research on AIDS, NIAID/NIH | GOOD | II. Clinical stage not reported
| USA | | | | | Female gender: 10% | B: Rifabutin 450 mg qD | MAC events (per 100 patient-years): 6.3 (4.2–8.3) vs. 10.5 (7.8–13.2) vs. 4.7 (2.9–6.5) (RR=0.56 [0.37–0.84], p=0.005 for A vs. B, RR=0.43 [0.27–0.69], p=0.003 for C vs. B, and RR 0.79 [0.48–1.31], p=0.36 for C vs. A) | Treatment-limiting toxicity (protocol defined or voluntary): 63/398 (15.8%) vs. 71/391 (18.2%) vs. 119/389 (30.8%), p<0.001
| | | | | | Median CD4: 29 cells/mm^3^ | C: Clarithromycin 500 mg bid + rifabutin 450 mg qD | Death (per 100 person-years): 29.1 (24.7–33.5) vs. 29.8 (25.3–34.4) vs. 32.2 (27.5–36.9) (RR=0.97 [0.78–1.20], p=0.79 for A vs. B, RR 0.89 [0.72–1.10], p=0.28 for A vs. C, and RR=0.92 [0.74–1.13], p=0.42 for C vs. B) | Gastrointestinal adverse events of grade 3 or higher severity: 5% vs. 5% vs. 2%
| | | | | | Median Karnofsky score: 90 | | | Laboratory adverse events of grade 3 or higher severity: 3.0% vs. 2.3% vs. 2.3%
| | | | | | Prior antiretroviral use: 74%
Havlir, 1996^612^ | RCT | Compare weekly azithromycin or daily rifabutin alone or in combination for MAC prophylaxis | Median 514 days | HIV infection, ≥18 years old, CD4 count <100 cells/mm^3^, Karnofsky score >60, no documented or suspected mycobacterial infection | 723 enrolled and 693 randomized | Mean age: 38 years | A: Rifabutin 300 mg qD | A vs. B vs. C | A vs. B. vs. C | California Universitywide AIDS Research Program Group, Pfizer, and Adria Laboratories | GOOD | II. High proportion with prior opportunistic infection
| USA | | | | | Female gender: 5% | B: Azithromycin 1200 mg qweek | Disseminated MAC: 52/223 (23%) vs. 31/223 (14%) vs. 18/218 (8%) | Any adverse event: 76% vs. 88% vs. 90%
| | | | | | Non-white race: 40% | C: Rifabutin 300 mg qD + Azithromycin 1200 mg qweek | Disseminated MAC at 1 year: 15% vs. 7% vs. 3% | Treatment-limiting toxicity: 16% vs. 13% vs. 23%
| | | | | | Mean CD4: 50 cells/mm^3^ | Patients also randomized to fluconazole 200 mg daily or 400 mg weekly | Pneumonia and sinusitis (episodes/100 patient-years): 20 vs. 10 vs. 5 (p<0.05 for A vs. B and A vs. C)
| | | | | | Prior OI: 40% | | Risk of MAC according to treatment group: HR (95% CI)
| | | | | | Prior rifabutin: 6% | | B vs. A: 0.53 (0.34–0.85)
| | | | | | Prior azithromycin: 2% | | C vs. A: 0.28 (0.16–0.49)
| | | | | | Prior clarithromycin: 4% | | C vs. B: 0.53 (0.29–0.95)
| | | | | | Fluconazole prophylaxis: 91% | | Death: 83/223 (37%) vs. 85/223 (38%) vs. 81/218 (37%)
Oldfield, 1998^608^ | RCT | Compare weekly azithromycin to placebo for MAC prophylaxis | Mean duration 400 days for azithromycin group and 340 days for placeo | HIV infection, ≥18 years old, CD4 count <100 cells/mm^3^, negative MAC blood cultures | 182 randomized | Mean age: 40 years | A: Azithromycin 1200 mg qweek | A vs. B | A vs. B | Pfizer, Military Medical Consortium for Applied Retroviral Research | GOOD | II. Clinical stage not reported
| USA | | | | | Female gender: 7% | B: Placebo | Disseminated MAC infection (ITT through 30 days after completion of therapy): 9/85 (10.6%) vs. 22/89 (24.7%) (HR 0.34, p=0.004) | Withdrawal due to adverse event: 7/85 (8.2%) vs. 2/89 (2.2%) (p=0.14)
| | | | | | Non-white race: 33% | | Death (ITT through 30 days after completion of therapy): 13/85 (15%) vs. 11//89 (12%) (HR 1.02, p=0.955) | At least 1 GI toxic effect: 71/90 (79%) vs. 25/91 (28%)
| | | | | | Mean CD4: 44 cells/mm^3^ | | Sinusitis (episodes per 100 patient years): 12 vs. 30 (RR 0.40 [0.19–0.81], p=0.010)
| | | | | | | | Pneumonia: 3 vs. 18 (RR 0.18 [0.05–0.640, p=0.008)
Pierce, 1996^609^ | RCT | Compare clarithromycin to placebo for MAC prophylaxis | Mean duration 10.5 months for azithromycin group and 9.5 months for placebo | HIV infection, CD4 count ≤100 cells/mm^3^, one negative blood culture for MAC, and Karnofsky score of ≥50 | 682 enrolled, 667 analyzed | Mean age: 38 years | A: Clarithromycin 500 mg bid | A vs. B | A vs. B | Abbott Laboratories | GOOD | II. Clinical stage not reported
| Europe and USA | | | | | Female gender: 9% | B: Placebo | MAC infections: 19/333 (6%) vs. 53/334 (16%), adjusted HR 0.31 (0.18–0.53), p<0.001 | Withdrawal due to adverse event or marked alteration in lab results: 56/182 (31%) vs. 41/175 (23%)
| | | | | | Non-white race: 14% | | Death: 107/333 (32%) vs. 137/334 (41%), adjusted HR 0.75 (0.58–0.97), p=0.026 | Any adverse event: 91% vs. 88% (p=0.59)
| | | | | | Median CD4: 30 vs. 25 cells/mm^3^ | | HIV-related condition: 283/333 (85%) vs. 295/334 (89%) | ‘Severe’ adverse events: 32% vs. 32%
| | | | | | Mean years since diagnosis of HIV: 4 years | | Hospitalization: 49% vs. 57% (HR 0.77 [0.61–0.96], p=0.020) | Adverse events possibly, probably, or definitely related to the study drug and unrelated to any concurrent condition: 42% vs. 26% (p<0.001)
| | | | | | Anemia or use of epoetin: 9% vs. 10%
Nightingale, 1993^610^ (1) | RCT | Compare rifabutin to placebo for MAC prophylaxis | Mean 214 days rifabutin group, 231 days placebo | Previous AIDS-defining event other than MAC infection, CD4 count ≤200 cells/mm^3^, PCP prophylaxis, and at least 4 wweeks of therapy with either AZT or DDI, two blood cultures and one stool culture negative for MAC | 590 | Median age: 37 years | A: Rifabutin 300 mg qD | A vs. B | A vs. B (combined with results of study 027) | Adria Laboratories and the Canadian HIV Clinical Trials Network | GOOD | II. High proportion with prior opportunistic infection | Some results combined with results of study 027. Survival analysis (including patients in study 027) including open-label follow-up and adjusting for Karnosky score, opportunistic infections, and use of rifabutin as a time-dependent variable, found relative hazard of dying while receiving rifabutin prophylaxis of 0.74 (0.60–0.91), p<0.004.
Study 023 | USA | | | | | Female gender: 4% | B: Placebo | New MAC infections up to 30 days after intervention: 24/292 (8%) vs. 51/298 (17%); RR 0.43 (0.26–0.70), p<0.001 | Therapy discontinued because of adverse events: 16% vs. 8%
| | | | | | Non-white race: 16% | | Hospitalization (combined with results of study 027): 180/566 (32%) vs. 218/580 (38%); RR 0.8, p=0.035 | Any adverse events: 51% vs. 50%
| | | | | | Mean CD4: 56 vs. 66 cells/mm^3^ | | Death through final analysis (combined with results of study 027): 200/566 (35%) vs. 226/580 (39%), p=0.137
| | | | | | Previous PCP: 56% | | Death up to 30 days after intervention (combined with results of study 027): 33/566 (6%) vs. 47/580 (8%); RR 0.68 (0.43–1.06), p=0.086
Nightingale, 1993^610^ (2) | RCT | Compare rifabutin to placebo for MAC prophylaxis | Mean 190 days rifabutin group, 185 days placebo | Previous AIDS-defining event other than MAC infection, CD4 count <=200 cells/mm^3^, PCP prophylaxis, and at least 4 weeks of therapy with either AZT or DDI, two blood cultures and one stool culture negative for MAC | 556 | Median age: 37 years | A: Rifabutin 300 mg qD | A vs. B | See results for study 023 | Adria Laboratories and the Canadian HIV Clinical Trials Network | GOOD | II. High proportion with prior opportunistic infection | Some results combined with results of study 023
Study 027 | USA and Canada | | | | | Female gender: 2.5% | B: Placebo | New MAC infections up to 30 days after intervention: 24/274 (9%) vs. 51/282 (18%); RR 0.47 (0.29–0.77), p=0.002
| | | | | | Non-white race: 8%
| | | | | | Median CD4: 55 vs. 61 cells/mm^3^
| | | | | | Previous PCP: 54%

MAC Mycobacterium avium complex

ITT Intention to Treat

PCP P. carinii pneumonia

AZT Zidovudine

DDI Didanosine

Evidence Table 7. Trials of CMV Prophylaxis

Author, year | Type of study/Setting | Aims | Duration of follow-up | Main eligibility criteria | Enrolled | Demographics / Baseline disease | Interventions | Clinical outcomes | Adverse events | Funding source | Internal validity rating | Relevance to screening | Comments
Brosgart, 1998^615^ | RCT | Evaluate efficacy of oral ganciclovir for preventing CMV disease in HIV-infected patients at high risk | Median 15 months | ≥13 years old, CD4 count ≤100, positive CMV immunoglobulin G serology or cuture without past or present CMV disease | 994 | Mean age: 40 years | A: Ganciclovir 1 g tid | A vs. B: number of events (events per 100 patient years) | A vs. B | National Institutes of Allergies and Infectious Diseases and the Terry Beirn CPCRA | GOOD | II. Clinical stage not reported | After mean follow-up of 9 months patients allowed to switch to open-label ganciclovir
| USA | | | | | Female gender: 5% | B: Placebo | Confirmed CMV disease: 101 (13.1) vs. 55 (14.6); HR 0.92 (0.65–1.27), p=0.60 | Withdrawal due to adverse events: 10% vs. not reported
| | | | | | Non-white race: 28% | | Confirmed CMV retinal disease: 75 (9.7) vs. 44 (11.7); HR 0.85 (0.59–1.24), p=0.40 | Any adverse event, number (rate per 100 patient-years): 250 (53.2) vs. 97 (38.9); HR 1.39 (1.09–1.76), p=0.008
| | | | | | Median CD4: 34 cells/mm^3^ | | Death: 222 (26.6) vs. 132 (32.0); HR 0.84 (0.67–1.04), p=0.09 | Grade IV or higher adverse event, number (rate per 100 patient-years): 188 (39.5) vs. 77 (30.7); HR 1.30 (0.99–1.71), p=0.06
| | | | | | On antiretroviral: 75% | | Confirmed CMV disease or death: 271 (34.8) vs. 158 (41.5); HR 0.84 (0.69–1.03), p=0.10 | Neutropenia, number (rate per 100 patient-years): 84 (16.2) vs. 38 (14.5); HR 1.12 (0.76–1.65), p=0.58
Spector, 1996^617^ | RCT | Evaluate efficacy of oral ganciclovir for preventing CMV disease in HIV-infected patients at high risk | Median 367 days | Adults, CD4 ≤50 (≤100 in those with a documented AIDS-defining opportunistic infection), CMV infection by antibody test or urine culture without evidence of disease | 725 | Median age: 38 years | A: Ganciclovir 1 g tid | A vs. B (12 month Kaplan-Meier estimates) | A (n=478) vs. B (n=234) | Roche Pharmaceuticals | GOOD | II. High proportion with prior opportunistic infection
| USA | | | | | Female gender: 1% | B: Placebo | Protocol-defined CMV events: 14% vs. 26%; RR 0.51 (0.36–0.73), p<0.001 | Discontinuation due to adverse events: 19% vs. 16%
| | | | | | Race: Not reported | | Protocol-defined CMV retinitis: 12% vs. 24%; RR 0.51 (0.35–0.75), p<0.001 | Gastrointestinal events: 77% vs. 74%
| | | | | | Antiretroviral treatment: 94% | | Incidence of herpes simplex virus: 3% vs. 7% (p<0.01) | Neuropathy: 21% vs. 15% (p=0.09)
| | | | | | Mean CD4 count: 26 cells/mm^3^ | | Death: 21% vs. 26%; RR 0.81 (0.61–1.07), p=0.14 | Severe neutropenia (ANC <500): 10% vs. 6% (p=0.1)
| | | | | | Prior OI: 54% | | CMV disease or death: 29% vs. 43%; RR 0.65 (0.51–0.84), p<0.001 | GCSF given: 24% vs. 9% (p<0.001)
Feinberg, 1998^616^ | RCT | Evaluate efficacy of valacyclovir and acyclovir for preventing CMV disease in HIV-infected patients at high risk | Median 56–60 weeks | ≥13 years old, CD4 count ≤100, prior evidence of CMV infection without CMV end-organ disease, had to be on all medications for HIV and opportunistic infections for at least 30 days | 1227 | Median age: 37 years | A: Valaciclovir 2 g qid | A vs. B or C | A vs. B vs. C | NIH, Australian National Council on AIDS, Netherlands National AIDS Therapy Evaluation Centre, and Glaxo Wellcome | GOOD | I
| USA, Australia, Canada, and Europe | | | | | Female gender: 6% | B: Acyclovir 800 mg qid | Confirmed CMV end-organ disease: 61/523 (11.7%) vs. 123/704 (17.5%); HR 0.71 (0.52–0.97) | 12-month discontinuation rate (any reason): 50.5% vs. 46.2% vs. 41.0%; p=0.01 for A vs. B or C
| | | | | | Non-white race: 20% | C: Acyclovir 400 mg bid | Estimated 12-month rates of confirmed CMV end-organ disease: 10% vs. 14.6% | GI events: More frequent in A; p=0.03
| | | | | | Median Karnofsky score: 90 | | Death: 223/523 (42.6%) vs. 135/353 (38.2%) vs. 130/351 (37.0%); p=0.06 for | Possible thrombotic microangiopathy: 14/523 (2.7%) vs. 1/353 (0.3%) vs. 3.351 (0.9%); p=0.008 for A vs. B or C
| | | | | | Median CD4: 32 cells/mm^3^ | | A vs. B and C
| | | | | | Any antiretroviral use: 21% | | Estimated 12-month rates of death: 24.1% vs. 19.5% vs. 18.8%
| | | | | | PCP prophylaxis: 96% | | Hazards ratios for death
| | | | | | | | A vs. C: HR 1.28 (1.03–1.59)
| | | | | | | | A vs. B: HR 1.17 (0.94–1.45)
| | | | | | | | B vs. C: 1.10 (0.87–1.40)

CMV Cytomegalovirus

OI Opportunistic Infection

PCP P. carinii pneumonia

GCSF Granulocyte Colony Stimulating Factor

Evidence Table 8. Observational Studies of Immediate vs. Deferred Initiation of Highly-Active Antiretroviral Therapy in Asymptomatic Patients with HIV Infection that Controlled for Lead-time Bias

Author, year | Type of study/ Setting | Aims | Study Duration | Eligibility criteria | Screened/Eligible/Enrolled population | Demographics / Baseline disease | Groups evaluated | Virologic response | Clinical outcomes | Internal validity rating | Relevance to screening | Comments
Opravil, 2002^644^ | Cohort study | Evaluate the efficacy of early initiation of highly active antiretroviral therapy | January 1996 to December 1999 | All asymptomatic patients with a CD4 cell count >350 × 10^6^/l, matched to asymptomatic participants who remained untreated during the following 12 months (matched for age, sex, CD4 cell count, viral load, and HIV risk category) | 6547 patients in cohort | Median age: 34 vs. 35 | A: HAART (defined as the combination of at least three antiretroviral drugs or any combination consisting of at least one PI) | A vs. B | A vs. B | GOOD | II. Did not stratify patients with CD4 counts above and below 200 cells/mm^3^ | 31% of untreated patients started antiretroviral therapy after 12 months.
Swiss HIV Cohort Study | Switzerland | | Duration of folllow-up 3.19 (treated) vs. 2.66 (untreated) years | | 312 treated patients eligible (not all could be matched) | Female: 28% vs. 30% | B: No HAART for 12 months after enrollment | Percent with HIV-1 RNA viral load <400 copies/ml at the end of follow-up: 182/283 (64%) vs. 86/283 (30%) (p<0.001) | Death: 6/283 (2.1%) vs. 18/283 (6.4%)
| | | | | 283 untreated and 283 treated evaluated | Non northwestern European nationality: 29% vs. 15% | | | Death (excluding accident, suicide, homicide, and drug overdose): 3/283 (1.1%) vs. 8/283 (2.8%)
| | | | | | Median CD4 cell count: 502 vs. 514 cells/mm^3^ | | | Percent with CDC stage B or C event: 18/283 (6.4%) vs. 60/283 (21.2%)
| | | | | | Median viral load: 4.23 vs. 4.08 log_10_ copies/ml | | | Percent with CDC stage C event: 5/183 (1.8%) vs. 15/283 (5.3%)
| | | | | | HCV seropositive: 28% vs. 28% | | | NNT with HAART for one year:
| | | | | | Injecting drug use: 21% vs. 21% | | | To prevent one CDC stage B/C event=18.3
| | | | | | High-school education: 14% vs. 12% | | | To prevent one new AIDS event=76
| | | | | | Missed appointments: 23% vs. 40% | | | To prevent one death from all causes=64
| | | | | | History of psychiatric consultation: 18% vs. 17% | | | To prevent one progression to either AIDS or death of ‘natural’ causes=68
| | | | | | | | | Adjusted hazards ratios (treated/untreated):
| | | | | | | | | Progression to a CDC B/C event: 0.19 (95% CI 0.11–0.33)
| | | | | | | | | Progression to AIDS: 0.23 (95% CI 0.08–0.68)
| | | | | | | | | Death of all causes: 0.20 (95% CI 0.07–0.52)
| | | | | | | | | AIDS or death of ‘natural causes’: 0.28 (95% CI 0.12–0.68)
Palella, 2003^638^ | Cohort study | To assess the survivial benefit of initiating antiretroviral therapy at different CD4 cell counts | January 1994 to March 2002 | HOPS cohort paticipants who had at least two CD4 measurements and reliable data on ART initiation and use for at least 30 consecutive days from January 1994 through March 2001. HAART defined as the use of at least three drugs simultaneously or two protease inhibitors | 1464 evaluated | Age: 40% younger than 40 years | A: HAART (defined as the combination of at least three antiretroviral drugs or any combination consisting of at least one PI) initiated while in baseline CD4 count stratum | A vs. B | A vs. B | GOOD | I
HIV Outpatient Study | USA | | Duration of follow-up 3.9–5.4 years in initiated group and 3.8–5.3 years in delayed group | | 399 had baseline CD4 count 201–350 | Gender: 31% female | B: HAART deferred until in lower CD4 count stratum | Percent with undetectable viral load at least measurement: | Deaths per 1000 patient-years in patients receiving HAART
| | | | | 327 had baseline CD4 count 351–500 | Non-white race: 38% | | Baseline CD4 count 201–350 cells/mm^3^: 32.4% vs. 22.0% (p=0.11) | Baseline CD4 201–350: 10.00 (11/265 deaths over 1099.7 patient years) vs. 36.29 (7/44/192.9) (Rate ratio 0.28 [0.11–0.71], p=0.004)
| | | | | 122 had baseline CD4 count 501–750 | Private insurance: 35% | | Baseline CD4 count 351–500 cells/mm^3^: 38.7% vs. 36.8% (p>0.2) | Baseline CD4 351–500: 4.83 (4/185/828.0) vs. 6.88 (2/65/290.7) (Rate ratio 0.70 [0.13–3.83], p>0.2)
| | | | | | | | Baseline CD4 count 501–750 cells/mm^3^: 29.1% vs. 26.9% (p>0.2) | Baseline CD4 501–750: 5.27 (1/32/189) vs. 3.06 (1/56/326.7) (Rate ratio 1.72 [0.11–27.5], p>0.2)
| | | | | | | | | Adjusted hazards ratio for death in patients initiating ART versus delayed ART
| | | | | | | | | Baseline CD4 201–350: 0.57 (p=0.16)
| | | | | | | | | Baseline CD4 351–500: 0.71 (p>0.2)
| | | | | | | | | Baseline CD4 501–750: Too few events
Sterling, 2003^640^ | Cohort | Compare clinical disease progression in patients for whom HAART initiated at CD4 count of 350–499 compared to those for whom it was not started | July 1996–June 2001 | All patients who began to receive HAART when they had a CD4 count of 350–499 and received >90 days of treatment, and all patients who did not receive treatment while in this stratum. | 333 enrolled | Age: median 36 vs. 38 years | A: Received HAART when CD4 count between 350 and 499 cells/mm^3^ | A vs. B | A vs. B | GOOD | II. Allowed antiretroviral-experienced patients | 23% in group B started HAART at counts of <350; 16% received non-HAART antiretroviral regimens
Johns Hopkins HIV Clinic Cohort | USA | | Median duration 30 months in treated versus 21 months in untreated | | | Female gender: 70% vs. 55% | B: Did not receive HAART when CD4 count between 350 and 499 cells/mm^3^ (no treatment or delayed treatment) | Percent with HIV-1 viral load <400 copies/ml at last visit: 74/159 (47%) vs. not reported | Death: 7/159 (4%) vs. 12/174 (7%) (p=-0.10)
| | | | | | Black race: 66% vs. 82% | | | Death or AIDS-defining events: 20/159 (13%) vs. 23/174 (13%) (NS)
| | | | | | Injection drug use: 35% vs. 56%
| | | | | | Baseline CD4: 416 vs. 423 cells/mm^3^
| | | | | | Baseline HIV-1 RNA load: 20,000 vs. 18151 copies/ml
| | | | | | Lost to follow-up: 6/159 (4%) vs. 5/174 (3%)
Ahdieh-Grant, 2003^639^ | Cohort | Compare risk of progression in groups immediately starting treatment compare to those delaying treatment in different CD4 count strata | July 1995–January 2000 | HIV-infected patients who had a CD4 count of 350–499 while AIDS-free and later reported use of HAART | 689 initiated HAART between July 1995 and January 2000; 349 met inclusion criteria | Deferred <200 vs. Deferred 200–349 vs. Immediate | A: Deferred therapy until CD4 count <200 cells/mm^3^ | Not reported | A vs. B vs. C | GOOD | II. High proportion of prior HAART use | Time to initiate treatment 4.3 years and 3.1 years for A and B.
MACS | USA | | | | | Median age: 39 vs. 40 vs. 43 (p=0.84) | B: Deferred therapy until CD4 count <350 cells/mm^3^ | | Progression to AIDS: 64/127 (50.4%) vs. 28/130 (21.5%) vs. 11/92 (12.0%); relative hazards 2.68 for A vs. C (p=0.003), 1.05 for B vs. C (p=0.897), and 2.56 for A vs. B (p<0.001)
| | | | | | Non-white race (%): 18% vs. 18% vs. 12% (p=0.990) | C: Immediate therapy with HAART
| | | | | | Prior antiretroviral therapy (%): 46 vs. 59 vs. 74 (p=0.040)
| | | | | | Median CD4 count: 424 vs. 415 vs. 410 (p=0.172) cells/mm^3^
| | | | | | Median viral load (log_10_): 4.53 vs. 4.44 vs. 4.35 (p=0.079)
| | | | | | Median number of years from first HIV-positive visit to index visit: 6.7 vs. 7.5 vs. 11.3 (p=0.006)

Evidence Table 9. Systematic Reviews of Effects of Testing and Counseling HIV-Infected Persons Regarding Risky Behaviors and Behavior Changes

Author, year | Type of study / Setting | Aims | Dates from which data analyzed | Population / Setting | Main eligibility criteria | Enrolled | Demographics | Interventions | Measures used | Main results | Conclusions / Recommendations | Limitations / Quality rating | Internal validity rating
Weinhardt, 1999^660^ | Meta-analysis of 27 studies | Evaluate whether HIV counseling and testing leads to reductions in sexual risk behavior | 1985 through June, 1997 | Populations and settings in nine countries | Published studies that provided sexual behavior outcome data, assessed behavior before and after counseling and testing, and provided details sufficient for calculation of effect size. | 19597 participants | Not reported | HIV testing and counseling | Not reported | HIV counseling and testing in HIV positive individuals and serodiscordant couples:; 1) Reduced unprotected intercourse: weighted mean effect sizes for the HIV positive group (d+=0.47; 95%CI=0.32, 0.61) and the serodiscordant couple group (d==0.75; 95% CI=0.59%, 0.92) indicated significant risk reduction, and both were greater than the weighted mean effect size for the untested participants (d+=0.16; 95% CI=0.07, 0.25, p,.001 and p,.001 respectively). HIV negative group did not reduce frequency of unprotected intercourse relative to untested participants.; 2) Condom use increased compared to HIV negative and untested participants. Weighted mean effect sizes for HIV positive and serodiscordant groups were positive, significant, homogenous and were greater than the mean effect size for untested participants (p<.001 and p<.001 respectively). HIV negative participants did not modify condom use more than those untested. Factors contributing to variance: age, volition for testing, IDU treatment status, sample seroprevalence, and length of follow-up. | HIV counseling and testing appears effective as a secondary intervention for those who are HIV positive, but in the reviewed studies was not an effective primary prevention strategy for uninfected participants. Theory-driven research is needed to further determine how HIV counseling and testing is effective. Effectiveness of specific counseling approaches should be examined. HIV counseling and testing should be viewed as part of an overall prevention strategy that includes individual, community, and policy level interventions. | Heterogeneity of effect sizes and the number of significant moderators suggests that response to HIV counseling and testing is complex. Most studies had a non-theoretical approach and were not informed by theories of behavior change. Assessing behavior change constructs before and after counseling and testing would permit stronger inferences about the effects of intervention. | GOOD
Effects of HIV counseling and testing on sexual risk behavior: A meta-analytic review of published research, 1985-1997 | | | | | | | | | | Number of sexual partners: Neither the HIV positive or negative groups exhibited greater change than the untested group. | | Literature included few details of counseling strategies.
| | | | | | | | | | HIV and STD: Incidence of STD infection decreased among HIV positive but increased among HIV negative and untested participants.
Wolitski, 1997^661^ | Systematic review | Reassess the data on ability of HIV counseling and testing (HIV CT) to motivate change in risk-related practices and to promote help-seeking behaviors | 1990 - August 1996 | Various settings and populations in the USA and elsewhere | Journal articles published in English with a longitudinal design assessing behavior before and following HIV CT or cross-sectional design comparing different CT histories or outcomes. Included studies: posttest counseling only, pre and posttest counseling | 35 domestic and international studies | Not reported | HIV testing and counseling | Not reported | 1) MSM: Risk-related behavior change documented but no consistent evidence of effects of HIV CT on sexual risk practices. Significant differences between HIV positive vs negative men in help-seeking behavior, which may be related to symptomatic disease progression and not HIV CT.; 2) IDUs and other drug users: Most studies showed positive changes in drug-related and sexual practices with HIV CT. HIV positives more likely to reduce risk behaviors than HIV negative or untested IDUs. A single study of help-seeking behavior found no significant differences.; 3) Women and heterosexual couples: Mixed findings on impact of serostatus knowledge on pregnancy rate, on impact of HIV CT on condom and other birth control use. Studies of HIV sero-discordant couples showed increase in condom use after HIV CT. One study showed decreased HIV and gonorrhea rates after HIV CT in some circumstances.; 4) Mixed populations: 3 of 4 studies on HIV positive found HIV CT was associated with reductions in sexual risk-related practices among those who knew they were HIV infected. Studies on HIV negatives did not show consistent evidence on effect of HIV CT. | The most consistent evidence for beneficial effects of HIV CT came from studies of heterosexual HIV-serodiscordant couples. Studies looking at serostatus and risk behavior usually found those who learned they were seropositive were more likely to adopt risk reducing practices than those who learned they were HIV negative. | Content and duration of counseling provided was poorly described and varied dramatically among studies. Few were specifically designed to evaluate effects of HIV CT. Methodological factors limit generalizability. | GOOD
The effects of HIV counseling and testing on risk-related practices and help-seeking behavior

CT Counseling and testing

Evidence Table 10. Studies* Evaluating Risk of Cardiovascular Events on Haart

Author, year | Type of study/ Setting | Aims | Duration of follow-up | Main eligibility criteria | Enrolled | Demographics / Baseline disease | Exposures | Clinical outcomes | Internal validity rating | Comments
Friis-Moller, 2003^739^ | Prospective cohort | Evalute risk of myocardial infarction in patients on combination antiretroviral therapy | Median follow-up 1.6 years | HIV-1 infected patients followed in partcipating clinics | 23468 | Median age: 39 years | A: Combination antiretroviral therapy: 74.5% | Incidence of myocardial infarction according to duration of exposure to combination therapy: | GOOD | Age, male gender, smoking status, lipid status and previous cardiovascular disase also associated with rate of MI in multivariate models. BMI, mode of transmission, race, family history of CAD not associated. Event rate 3.5 MI/1,000 person-years; 5.7 cardio- and cerebrovascular events/1,000 person-years
The Writing Committee of the DAD Study Group, 2004^740^ | Europe, USA, Australia | | | | | Female gender: 24% | B: Any antiretroviral therapy: 80.8% | Exposure (years): RR compared to <1 year exposure (p for trend <0.001)
Data Collection on Adverse Events of Anti-HIV Drugs (DAD) Study | | | | | | Race: Not reported | C: No antiretorivral therapy: 19.2% | No exposure: 0.24 (0.08–0.89)
| | | | | | Median duration of HIV-1 infection: 3.5 years | | 1–2 years: 1.34 (0.58–3.10)
| | | | | | Baseline median CD4: 418 cells/mm^3^ | | 2–3 years: 1.73 (0.80–3.76)
| | | | | | Baseline viral load (log_10_ copies/ml): <2.7 | | 3–4 years: 1.98 (0.94–4.15)
| | | | | | No prior antiretroviral therapy: 19% | | >4 years: 2.55 (1.25–5.20)
| | | | | | Current or former smoker: 56% | | Adjusted (for total cholesterol, triglycerides, HTN, DM, lipodystrophy, duration of HIV-1 infection, AIDS before enrollment, CD4 count, HIV-1 RNA level) RR for myocardial infarction per additional year of exposure: 1.26 (1.12–1.41)
| | | | | | Family history of coronary heart disease: 12% | | Adjusted RR for cardio- and cerebrovascular events (myocardial infarction, invasive cardiovascular procedures, stroke, or death from other cardiovascular diseases) per additional year of exposure: 1.26 (1.14–1.38)
| | | | | | Previous cardiovascular disease: 1.5%
| | | | | | HTN: 7%
| | | | | | Diabetes: 3%
| | | | | | Dyslipidemia: 46%
Holmberg, 2002;^744^ updated results 2004^743^ | Prospective cohort | Evaluate risk of myocardial infarction in patients on protease inhibitors | 17172 person-years of observation | HIV-1 infected patients followed in participating clinics | 5672 | Mean age: 43 years | A: Protease inhibitor use: 3247/5672 (57%) | A vs. B | GOOD | Rate of MI decreased from 3.10/1,000 person-years in 2000 to 1.91/1,000 person-years in 2002; protease inhibitor use declined from 76% in 1998 to 58% in 2002 and statin use increased from 4% to 15%.
| USA | | | | | Female gender: 18% | B: No protease inhibitor use: 43% | Rate of myocardial infarction (per 1,000 person-years): 1.42 (19/3247 patients) vs. 0.46 (2/2425); p=0.002
| | | | | | Non-white race: 38% | | Adjusted (for HTN, smoking, DM, Age, gender, dyslipidemia) HR for myocardial infarction, A vs. B: 6.51 (0.89–47.8)
| | | | | | HTN: 11%
| | | | | | Smoking: 56%
| | | | | | DM: 4.5%
| | | | | | Dyslipidemia: 28%
| | | | | | Baseline CD4 count and viral load not reported
Klein, 2002^749^ | Retrospective cohort | Evaluate risk of myocardial infarction and coronary heart disease in patients receiving protease inhibitors or any antiretroviral therapy | Mean duration 3.6 years | HIV-1 infected members of Kaiser Permanente Medical Care Program of Northern California | 4159 | Mean age: 46 years | A: Protease inhibitor exposure: 6793 person-years | A vs. B vs. C vs. D | GOOD | Overall rate of CHD hospitalizations 6.5/1,,000 person-years in HIV+ vs. 3.8 in HIV-; MI hospitalization rate 4.3 vs. 2.9.
| USA | | | | | Female gender: Not included in study | B: No protease inhibitor exposure: 8030 person-years | Age adjusted rate of coronary heart disease hospitalization, per 1,000 person-years (95% CI): 6.7 (4.4–9.1) vs. 6.2 (3.5–8.9) vs. 6.8 (4.7–8.8) vs. 5.7 (2.1–9.3)
| | | | | | Non-white race: 31% | C: Any antiretoviral exposure: 10834 person-years | Age adjusted rate of MI hospitalization, per 1,000 person-years (95% CI) (A vs. B)
| | | | | | Baseline CD4 count and viral load: Not reported | D: No antiretroviral exposure: 3913 person-years | 4.3 (2.4–6.1) vs. 4.4 (2.0–6.7)
| | | | | | HTN: 18%
| | | | | | Hyperlipidemia: 21%
| | | | | | DM: 7%
| | | | | | Current smoker: 19%
Barbaro, 2003^745^ | Prospective cohort | Evaluate risk of coronary artery-disease related events in patients receiving 3 drugs with a protease inhibitor or an NNRTI | Median duration 36 months | Previously untreated and asymptomatic patients at participating centers | 1551 | Median age: 35 years | A: 2 NRTI + 1 PI | A vs. B | FAIR | CAD-related events primarily seen in young, male, heavy smokers who develop metabolic disorders and lipodystrophy with therapy with PI's.
| Italy | | | | | Female gender: 36% | B: 2 NRTI + 1 NNRTI | CAD-related events (recently developed angina, unstable angina, and myocardical infarction) (per 1,000 patient-years): 9.8 vs. 0.8 (p<0.001) | Investigators not blinded to exposure
| | | | | | Race: Not reported | | MI (per 1,000 patient-years): 5.1 vs. 0.4 (p<0.001)
| | | | | | Median CD4 count: 325 vs. 350 cells/mm^3^ | | Lipodystrophy: 62% vs. 4% (p<0.001); adjusted RR 5.4 (3.78–7.92)
| | | | | | Median viral load (log_10_ copies/ml): 5.4 vs. 5.1
| | | | | | CDC class A1: 16%
| | | | | | Median plasma glucose: 94% vs. 98%
| | | | | | Median serum cholesterol: 150 vs. 160
| | | | | | Heavy smoker: 47%
Currier, 2003^750^ | Retrospective cohort (population-based) | Evaluate risk of coronary heart disease in patients receiving antiretroviral therapy | Median 2.50 years | Medicaid population, receiving antiretroviral therapy or if a medical claim with HIV diagnosis code present | 28513 | Age 44 or younger: 70% | A: Antiretroviral experienced | A vs. B: Adjusted (for diabetes, hyperlipidemia, renal failure, hypertension) RR (95% confidence interval) | GOOD | Age-adjusted all-cause mortality in patients with HIV and CHD: 5.06 per 100 patient-years. Incidence of CHD 0.77/100 PY in men 18–24 to 5.55/100 PY in men 75 or greater. HIV-infected men age 18–24 0.77 case/100 PY vs. non-infected 0.11 case/100 PY. Overall rate of MI in HIV-infected patients 1.03%.
| 2003 | | | | | Female gender: 27% | B: Antiretroviral naïve | New coronary heart disease diagnosis
| | | | | | Race/ethnicity: Not reported | C: HIV-infected | Age 18–33: 2.06 (1.42–2.99); p<0.005
| | | | | | Baseline disease: Not reported | D: Not HIV-infected | Age 34–49: 1.08 (0.91–1.28)
| | | | | | Cardiac risk factors: Not reported | | Age 50–65: 0.79 (0.63–1.00)
| | | | | | | | Age 66 or older: 1.15 (0.65–2.04)
| | | | | | | | C vs. D: Adjusted RR (95% CI)
| | | | | | | | New coronary heart disease diagnosis in men
| | | | | | | | Age 18–24: 6.76 (3.36–13.58); p<0.0001
| | | | | | | | Age 25–34: 2.16 (1.81–2.58); p <0.0001
| | | | | | | | Age 35–44: 1.06 (0.96–1.18); p=0.26
| | | | | | | | Age 45–54: 0.82 (0.73–0.92); p=0.0007
| | | | | | | | Age 55–64: 0.60 (0.51–0.71); p<0.0001
| | | | | | | | Age 65–74: 0.55 (0.39–0.77); p=0.0006
| | | | | | | | Age 75 or older: 0.86 (0.53–1.50); p=0.5437
| | | | | | | | New coronary heart disease diagnosis in women
| | | | | | | | Age 18–24: 2.47 (1.23–4.95); p=0.011
| | | | | | | | Age 25–34: 1.53 (1.10–2.13); p=0.011
| | | | | | | | Age 35–44: 1.67 (1.41–1.97); p<0.0001
| | | | | | | | Age 45–54: 0.86 (0.71–1.04); p=0.116
| | | | | | | | Age 55–64: 0.70 (0.54–0.90); p=0.006
| | | | | | | | Age 65–74: 0.73 (0.51–1.05); p=0.087
| | | | | | | | Age 75 or older: 0.76 (0.48–1.21); p=0.253
Coplan, 2003^742^ | Meta-analysis of RCTs | Evaluate risk of myocardial infarction in patients on protease inhibitors | Mean 1 year (8789 patient-years) | Participants in phas II/III industry=sponsored, double-blinded, RCTs involving the first four licensed protease inhibitors | 10986 | Mean age: 37 years | A: Protease inhibitor (patient-years) | A vs. B | FAIR | Indinavir, nelfinavir, ritonavir, and saquinavir hard-gel formulation evaluated. Rate of CAD in non-PI exposed patients similar to community studies.
| Settings not described | | | | | Female gender: 14% | B: Non-protease inhibitor-containing regimens (patient-years) | MI rate, intention-to-treat analysis of randomized phases (events per 1,000 patient-years): 1.38 (7 cases/5,060 PY) vs. 1.18 (3/2,560) (RR 1.18 [0.32–4.41]) | Investigators not blinded to exposure
| | | | | | Race: Not reported | | MI rate, including open-label follow-up: 1.82 (16/8,789) vs. 1.05 (3/2,862) (RR 1.69 [0.54–7.48])
| | | | | | Baseline disease: Not reported
| | | | | | Cardiovascular risk factors: Not reported
Coplan, 2001^810^ | Meta-analysis of RCTs Settings not described | Evaluate risk of myocardial infarction in patients on indinavir | 1922.5 patient-years of follow-up on indinavir | Participants in 4 Merck-sponsored phase III active-control trials of indinavir | 2680 (894 indinavir monotherapy, 886 NRTI-only, 900 indinavir combination therapy) | Demographics not reported | A: Indinavir (patient-years) | A vs. B | FAIR | Studies may have also been evaluated in Coplan, 2003 (not clear).
| | | | | | Baseline disease: Not reported | B: NRTI-only therapy | MI rate (events per 1,000 patient-years): 2.08 vs. 2.97 (RR 0.70 [0.12–5.48]) | Not clear how studies selected
| | | | | | Cardiovascular risk factors: Not reported | | All cardiovascular events (MI, angina, unexplained death, stroke, peripheral vascular disease; events per 1,000 PY): 5.93 vs. 5.74 (RR 0.97 [0.32–3.51])
Jutte, 1999^747^ | Retrospective cohort | Evaluate risk of myocardial infarction in patients on protease inhibitors | Mean 1.26 years in patients receiving PI | Patients with HIV without a history of coronary heart disease prior to starting protease inhibitor treatment | 1324 (951 no PI, 373 receive PI) | Demographics not reported | A: Received protease inhibitor | A vs. B | FAIR
| Germany | | | | | Baseline disease: Not reported | B: No protease inhibitor | MI rate (events per 100 patient-years): 1.06 vs. 0.21; p=0.025 | Did not control for confounders
| | | | | | Cardiovascular risk factors: Not reported
Mary-Krause, 2003^746^ | Prospective cohort | Evaluate risk of myocardial infarction in male patients on protease inhibitors | Median 32 months | HIV-1 infected men in the French Hospital Database on HIV | 34976 men | Patients without myocardial infarction versus patients with myocardial infarction | A: Exposed to PI for >=30 months | MI incidence (standardized morbidity ratio [95% CI]) | FAIR | Incidence of MI per 10,000 person-years (95% CI)
| France | | | | | Mean age: 38 vs. 42 years | B: Exposed to PI for 18–29 months | A vs. C: 3.6 (1.8–6.2) | Not clear if investigators blinded to exposure | <6 months PI: 3.98 (0.08–7.89
| | | | | | Median first CD4 count: 249 vs. 202 cells/mm^3^ | C: Exposed to PI for <18 months | B vs. C: 1.9 (1.0–3.1) | | 6–11 months: 10.49 (3.64–17.35)
| | | | | | Cardiovascular risk factors: Not reported | | | | 12–17months: 11.24 (3.45–19.02)
| | | | | | | | | | 18–23 months: 14.49 (4.45–24.53)
| | | | | | | | | | 24–29 months: 17.86 (4.63–31.09)
| | | | | | | | | | 30–35 months: 49.00 (21.28–76.72)
| | | | | | | | | | >=36 months: 8.82 (0.00–26.01)
Leport, 2002^748^ | Retrospective cohort (not clear) | Evaluate risk of coronary heart disease risk in patients receiving protease inhibitors | Mean duration of follow-up not reported | HIV-1 infected men from the French APROCO cohort 12–20 months after starting protease inhibitors | 223 HIV+ men receiving PI and 527 matched controls | Demographics not reported | A: Protease inhibitor in HIV+ men | A vs. B | Insufficient data on methods to rate quality, but exposure groups do not appear adequately matched | Abstract only
(abstract only) | France | | | | | Baseline disease: Not reported | B: General population sample | CHD risk: Relative risk 1.20 (p<0.00001)
| | | | | | Hypertension: 5% vs. 13%
| | | | | | Smoking: 57% vs. 33%
| | | | | | Diabetes: 2% vs. 3%
| | | | | | Lipids: Similar

* Excluding ecologic studies evaluating time-trends in cardiovascular complication rates