# References

1 Centers for Disease Control and Prevention. 1993 revised classification system for HIV infection and expanded surveillance case definition for AIDS among adolescents and adults. Morb Mortal Wkly Rep. 1992;41(RR-17):1-19.
2 Centers for Disease Control and Prevention. HIV/AIDS Surveillance Report. US Department of Health and Human Services, Centers for Disease Control and Prevention. Available at: http://www.cdc.gov/hiv/stats/2003SurveillanceReport.pdf. Accessed March 22, 2005.
3 Centers for Disease Control and Prevention. Advancing HIV prevention: New strategies for a changing epidemic—United States, 2003. Morb Mortal Wkly Rep. 2003;52(15):329-332.
4 Fleming P, Byers RH, Sweeney PA, et al. HIV prevalence in the United States, 2000. Paper presented at: The 9th Conference on Retroviruses and Opportunistic Infections. February 24–28, 2002; Seattle, WA.
5 Centers for Disease Control and Prevention. Unrecognized HIV infection, risk behaviors, and perceptions of risk among young black men who have sex with men - six U.S. cities, 1994-1998. Morb Mortal Wkly Rep. 2002;51(33):733-736.
6 Centers for Disease Control and Prevention. Increases in HIV diagnoses—29 states, 1999-2002. Morb Mortal Wkly Rep. 2003;52(47):1145-1148.
7 Centers for Disease Control and Prevention. HIV and AIDS - United States, 1981-2000. Morb Mortal Wkly Rep. 2001;50(21):430-434.
8 Karon JM, Rosenberg PS, McQuillan G, et al. Prevalence of HIV infection in the United States, 1984 to 1992. JAMA. 1996;276(2):126-131. [pmid: 8656504].
9 Rosenberg PS, Biggar RJ, Goedert JJ. Declining age at HIV infection in the United States. N Engl J Med. 1994;330(11):789-790. [pmid: 8107749].
10 Wortley PM, Fleming PL. AIDS in women in the United States. JAMA. 1997;278(11):911-916. [pmid: 9302243].
11 Kochanek KD, Smith BL. Deaths: Preliminary Data for 2002. National vital statistics reports; Vol. 52, No. 13. Division of Vital Statistics. Centers for Disease Control. Available at: http://www.cdc.gov/nchs/data/nvsr/nvsr52/nvsr52_13.pdf. Accessed March 28, 2005.
12 Bozzette SA, Berry SH, Duan N, et al. The care of HIV-infected adults in the United States. N Engl J Med. 1998;339(26):1897-1904. [pmid: 9862946].
13 Landon BE, Wilson IB, Cohn SE, et al. Physician specialization and antiretroviral therapy for HIV. J Gen Intern Med. 2003;18:233-241. [pmid: 12709089]. [pmcid: 1494839].
14 Department of Health and Human Services. Guidelines for the use of antiretroviral agents in HIV-1-infected adults and adolescents. 2004;2005(March 28).
15 Yeni PG, Hammer SM, Hirsch MS, et al. Treatment for adult HIV infection: 2004 recommendations of the International AIDS Society - USA Panel. JAMA. 2004;292(2):251-265. [pmid: 15249575].
16 McNaghten AD, Hanson DL, Jones JL, et al. Effects of antiretroviral therapy and opportunistic illness primary chemoprophylaxis on survival after AIDS diagnosis. Adult/Adolescent Spectrum of Disease Group. AIDS. 1999;13(13):1687-1695. [pmid: 10509570].
17 Centers for Disease Control and Prevention. Guidelines for preventing opportunistic infections among HIV-infected persons—2002 recommendations of the U.S. Public Health Service and the Infectious Diseases Society of America. Morb Mortal Wkly Rep. 2002;51(RR-8):1-52.
18 Centers for Disease Control and Prevention. Recommended adult immunization schedule by age group and medical conditions United States, 2003-2004. Available at: http://www.cdc.gov/nip/recs/adult-schedule.pdf. Accessed June 28, 2004.
19 Centers for Disease Control and Prevention. Late versus early testing of HIV - 16 sites, United States, 2000-2003. Morb Mortal Wkly Rep. 2003;52(25):581-585.
20 Raffi F, Chene G, Lassalle R, et al. Progression to AIDS or death as endpoints in HIV clinical trials. HIV Clinical Trials. 2001;2(4):330-335. [pmid: 11590536].
21 Gallo RC, Montagnier L. The Discovery of HIV as the Cause of AIDS. N Engl J Med. 2003;349(24):2283-2285. [pmid: 14668451].
22 Larder BA. Viral resistance and the selection of antiretroviral combinations. J Acquir Immune Defic Syndr Hum Retrovirol. 1995;10(Suppl 1):S28-33. [pmid: 8595505].
23 Larder BA, Kemp SD. Multiple mutations in HIV-1 reverse transcriptase confer high-level resistance to zidovudine (AZT). Science. 1989;246(4934):1155-1158. [pmid: 2479983].
24 Larder BA, Darby G, Richman DD. HIV with reduced sensitivity to zidovudine (AZT) isolated during prolonged therapy. Science. 1989;243:1731-1734. [pmid: 2467383].
25 Ho DD, Neumann AU, Perelson AS, et al. Rapid turnover of plasma virions and CD4 lympohcytes in HIV-1 infection. Nature. 1995;373:123-126. [pmid: 7816094].
26 Wei X, Ghosh SK, Taylor ME, et al. Viral dynamics in human immunodeficiency virus type 1 infection. Nature. 1995;373:117-122. [pmid: 7529365].
27 Clavel F, Hance AJ. HIV Drug Resistance. N Engl J Med. 2004;350(10):1023-1035. [pmid: 14999114].
28 Nathanson N, Mathieson BJ. Biological considerations in the development of a human immunodeficiency virus vaccine. J Infect Dis. 2000;182:579-589. [pmid: 10915092].
29 Letvin NL. Progress in the Development of an HIV-1 Vaccine. Science. 1998;280(5371):1875-1880. [pmid: 9632379].
30 Bangham CRM, Phillips RE. What is required of an HIV vaccine?. Lancet. 1997;350:1617-1621. [pmid: 9393353].
31 Chakraborty H, Sen PK, Helms RW, et al. Viral burden in genital secretions determines male-to-female sexual transmission of HIV-1: a probabilistic empiric model. AIDS. 2001;15:621-627. [pmid: 11317000].
32 Kovacs A, Wasserman SS, Burns D, et al. Determinants of HIV-1 shedding in the genital tract of women. Lancet. 2001;358:1593-1601. [pmid: 11716886].
33 Stebbing J, Gazzard B, Douek DC. Where does HIV live?. N Engl J Med. 2004;350(18):1872-1880. [pmid: 15115833].
34 Kiviat NB, Critchlow CW, Hawes SE, et al. Determinants of human immunodeficiency virus DNA and RNA shedding in the anal-rectal canal of homosexual men. J Infect Dis. 1998;177:571-578. [pmid: 9498434].
35 Rothenberg RB, Scarlett M, del Rio C, et al. Oral transmission of HIV. AIDS. 1998;12(16):2095-2105. [pmid: 9833850].
36 Corey L, Wald A, Celum CL, et al. The effect of herpes simplex virus-2 on HIV-1 acquisition and transmission: a review of two overlapping epidemics. J Acquir Immune Defic Syndr. 2004;35(5):435-445. [pmid: 15021308].
37 Cohen MS. Sexually transmitted diseases enhance HIV transmission: no longer a hypothesis. Lancet. 1998;351(Suppl 3):5-7. [pmid: 9652712].
38 Wasserheit JN. Epidemiological synergy: interrelationships between human immunodeficiency virus infection and other sexually transmitted diseases. Sex Transm Dis. 1992;19:61-77. [pmid: 1595015].
39 Fleming DT, Levine WC, Trees DL, et al. Syphilis in Atlanta during an era of declining incidence. Sex Transm Dis. 2000;27(2):68-73. [pmid: 10676972].
40 Quinn TC, Glasser D, Cannon RO, et al. Human immunodeficiency virus infection among patients attending clinics for sexually transmitted diseases. N Engl J Med. 1988;318(4):197-203. [pmid: 3336411].
41 Padian NS, Shiboski SC, Glass SO, et al. Heterosexual transmission of human immunodeficiency virus (HIV) in Northern California: results from a ten-year study. Am J Epidemiol. 1997;146(4):350-357. [pmid: 9270414].
42 Quinn TC, Cannon RO, Glasser D, et al. The association of syphilis with risk of human immunodeficiency virus infection in patients attending sexually transmitted disease clinics. Arch Intern Med. 1990;150(6):1297-1302. [pmid: 2353862].
43 Schoenbaum EE, Webber MP, Vermund S, et al. HIV antibody in persons screened for syphilis: prevalence in a New York City emergency room and primary care clinics. Sex Transm Dis. 1990;17(4):190-193. [pmid: 2264007].
44 Wald A, Link K. Risk of human immunodeficiency virus infection in herpes simplex virus type 2-seropositive persons: a meta-analysis. J Infect Dis. 2002;185(1):45-52. [pmid: 11756980].
45 McQuillan GM, Ezzati-Rice TM, Siller AB, et al. Risk behavior and correlates of risk for HIV infection in the Dallas County Household HIV survey. Am J Public Health. 1994;84(5):747-753. [pmid: 8179043]. [pmcid: 1615040].
46 Page-Shafer K, Veugelers PJ, Moss AR, et al. Sexual risk behavior and risk factors for HIV-1 seroconversion in homosexual men participating in the Tricontinental Seroconverter Study, 1982-1994. Am J Epidemiol. 1997;146(7):531-542. [pmid: 9326430].
47 Leynaert B, Downs AM, de Vincenzi I. Heterosexual transmission of human immunodeficiency virus: variability of infectivity throughout the course of infection. Am J Epidemiol. 1998;148(1):88-96. [pmid: 9663408].
48 European Study Group on Heterosexual Transmission of HIV. Comparison of female to male and male to female transmission of HIV in 563 stable couples. BMJ. 1992;304:809–813.
49 European Study Group. Risk factors for male to female transmission of HIV. BMJ. 1989;298(6671):411-415. [pmid: 2495045]. [pmcid: 1835678].
50 Lee T-H, Sakahara N, Fiebig E, et al. Correlation of HIV-1 RNA levels in plasma and heterosexual transmission of HIV-1 from infected transfusion recipients. J Acquir Immune Defic Syndr Hum Retrovirol. 1996;12:427-428. [pmid: 8673554].
51 Operskalski EA, Stram DO, Busch MP, et al. Role of viral load in heterosexual transmission of human immunodeficiency virus type 1 by blood transfusion recipientss. Am J Epidemiol. 1997;146(8):655-661. [pmid: 9345119].
52 Quinn TC, Wawer MJ, Sewankambo N, et al. Viral load and heterosexual transmission of human immunodeficiency virus type 1. N Engl J Med. 2000;342(13):921-929. [pmid: 10738050].
53 Mastro TD, Kitayaporn D. HIV type 1 transmission probabilities: estimates from epidemiological studies. AIDS Res Hum Retroviruses. 1998;14(Suppl 3):S223-227. [pmid: 9814947].
54 Vittinghoff E, Douglas J, Judson F, et al. Per-contact risk of human immunodeficiency virus transmission between male sexual partners. Am J Epidemiol. 1999;150(3):306-311. [pmid: 10430236].
55 del Romero J, Marincovich B, Castilla J, et al. Evaluating the risk of HIV transmission through unprotected orogenital sex. AIDS. 2002;2002:1296-1297. [pmid: 12045500].
56 Padian NS, Shiboski SC, Jewell NP. Female-to-male transmission of human immunodeficiency virus. JAMA. 1991;266(12):1664-1667. [pmid: 1886189].
57 Nicolosi A, Correa Leite ML, Musicco M, et al. The efficiency of male-to-female and female-to-male transmission of the human immunodeficiency virus: a study of 730 stable couples. Epidemiology. 1994;5(6):570-575. [pmid: 7841237].
58 Jose B, Friedman SR, Neaigus A, et al. Syringe-mediated drug-sharing (backloading): a new risk factor for HIV among injecting drug users. AIDS. 1993;7:1653-1660. [pmid: 8286076].
59 Doherty MC, Garfein RS, Monterroso E, et al. Correlates of HIV infection among young adult short-term injection drug users. AIDS. 2000;14:717-726. [pmid: 10807195].
60 Nemoto T. Behavioral characteristics of seroconverted intravenous drug users. Int J Addict. 1992;27(12):1413-1421. [pmid: 1452392].
61 Kahn JO, Walker BD. Acute human immunodeficiency virus type 1 infection. N Engl J Med. 1998;339(1):33-39. [pmid: 9647878].
62 Schacker T, Collier AC, Hughes J, et al. Clinical and epidemiologic features of primary HIV infection. Ann Intern Med. 1996;125(4):257-264. [pmid: 8678387].
63 Vanhems P, Allard R, Cooper DA, et al. Acute human immunodeficiency virus type 1 disease as a mononucleosis-like illness: is the diagnosis too restrictive?. Clin Infect Dis. 1997;24(5):965-970. [pmid: 9142802].
64 Daar ES, Little S, Pitt J, et al. Diagnosis of primary HIV-1 infection. Ann Intern Med. 2001;134(1):25-29. [pmid: 11187417].
65 Pincus JM, Crosby SS, Losina E, et al. Acute human immunodeficiency virus infection in patients presenting to an urban urgent care center. Clin Infect Dis. 2003;37(12):1699-1704. [pmid: 14689354].
66 Daar ES, Moudgil T, Meyer RD, et al. Transient high levels of viremia in patients with primary human immunodeficiency virus type 1 infection. N Engl J Med. 1991;324(14):961-964. [pmid: 1823118].
67 Pilcher CD, Tien HC, Eron Jr JJ, et al. Brief but efficient: acute HIV infection and the sexual transmission of HIV. J Infect Dis. 2004;189(10):1785-1792. [pmid: 15122514].
68 Touloumi G, Pantazis N, Babiker AG, et al. Differences in HIV RNA levels before the initiation of antiretroviral therapy among 1864 individuals with known HIV-1 seroconversion dates. AIDS. 2004;18:1697-1705. [pmid: 15280781].
69 Schacker TW, Hughes JP, Shea T, et al. Biological and virologic characteristics of primary HIV infection. Ann Intern Med. 1998;128(8):613-620. [pmid: 9537934].
70 Henrard DR, Phillips JF, Muenz LR, et al. Natural history of HIV-1 cell-free viremia. JAMA. 1995;274(7):554-558. [pmid: 7629984].
71 Rodes B, Toro C, Paxinos E, et al. Differences in disease progression in a cohort of long-term non-progressors after more than 16 years of HIV-1 infection. AIDS. 2004;18(8):1109-1116. [pmid: 15166526].
72 Schrager LK, Young JM, Fowler MG, et al. Long-term survivors of HIV-1 infection: definition and research challenges. AIDS. 1994;8(Suppl 1):S95-S108. [pmid: 7857574].
73 Sheppard HW, Lang W, Ascher MS, et al. The characteriazation of non-progressors: long-term HIV-1 infection with stable CD4+ T-cell levels. AIDS. 1993;7:1156-1166.
74 Learmont J, Tindall B, Evans L, et al. Long-term symptomless HIV-1 infection in recipients of blood products from a single donor. Lancet. 1992;340:863-867. [pmid: 1357294].
75 Easterbrook PJ. Non-progression in HIV infection. AIDS. 1994;8(1179–1182).
76 Buchbinder SP, Katz MH, Hessol NA, et al. Long-term HIV-1 infection without immunologic progression. AIDS. 1994;8(8):1123-1128. [pmid: 7986410].
77 Collaborative Group on AIDS Incubation and HIV Survival including the CASCADE EU Concerted Action. Time from HIV-1 seroconversion to AIDS and death before widespread use of highly-active antiretroviral therapy: a collaborative re-analysis. Lancet. 2000;355:1131–1137.
78 Koblin BA, van Benthem BH, Buchbinder SP, et al. Long-term survival after infection with human immunodeficiency virus type 1 (HIV-1) among homosexual men in hepatitis B vaccine trial cohorts in Amsterdam, New York City, and San Francisco, 1978-1995. Am J Epidemiol. 1999;150(10):1026-1030. [pmid: 10568617].
79 Stein DS, Korvick JA, Vermund SH. CD4+ lymphocyte cell enumeration for prediction of clinical course of human immunodeficiency virus disease: a review. J Infect Dis. 1992;165:352-363. [pmid: 1346152].
80 Kaslow RA, Phair JP, Friedman HB, et al. Infection with the human immunodeficiency virus: clinical manifestations and their relationship to immune deficiency. Ann Intern Med. 1987;107(4):474-480. [pmid: 2957944].
81 Cascade Collaboration. Short-term risk of AIDS according to current CD4 cell count and viral load in antiretroviral drug-naive individuals and those treated in the monotherapy era. AIDS. 2004;18(1):51-58. [pmid: 15090829].
82 Polk BF, Fox R, Brookmeyer R, et al. Predictors of the acquired immunodeficiency syndrome developing in a cohort of seropositive homosexual men. N Engl J Med. 1987;316(2):61-66. [pmid: 3024007].
83 Hanson DLMS, Chu SYP, Farizo KMMD, et al. Distribution of CD4 sup + T Lymphocytes at Diagnosis of Acquired Immunodeficiency Syndrome-Defining and Other Human Immunodeficiency Virus-Related Illnesses. Arch Intern Med. 1995;155(14):1537-1542. [pmid: 7605156].
84 Saravolatz L, Neaton JD, Sacks L, et al. CD4+ T lymphocyte counts and patterns of mortality among patients infected with human immunodeficiency virus who were enrolled in community programs for clinical research on AIDS. Clin Infect Dis. 1996;22:513-520. [pmid: 8852972].
85 Yarchoan R, Venzon DJ, Pluda JM, et al. CD4 count and the risk for death in patients infected with HIV receiving antiretroviral therapy. Ann Intern Med. 1991;115(3):184-189. [pmid: 1676252].
86 Phillips AN, Lee CA, Elford J, et al. Serial CD4 lymphocyte counts and development of AIDS. Lancet. 1991;337(8738):389-392. [pmid: 1671424].
87 Mellors JW, Munoz A, Giorgi JV. Plasma viral load and CD4+ lymphocytes as prognostic markers of HIV-1 infection. Ann Intern Med. 1997;126(12):946-954. [pmid: 9182471].
88 Egger M, May M, Chene G, et al. Prognosis of HIV-1-infected patients starting highly active antiretroviral therapy: a collaborative analysis of prospective studies. Lancet. 2002;360(9327):119-129. [pmid: 12126821].
89 Centers for Disease Control and Prevention. Revision of the CDC surveillance case definition for acquired immunodeficiency syndrome. Morb Mortal Wkly Rep. 1987;36:1-15S.
90 Swindells S, Evans S, Zackin R, et al. Predictive value of HIV-1 viral load on risk for opportunistic infection. J Acquir Immune Defic Syndr. 2002;30(2):154-158. [pmid: 12045677].
91 Kaplan JE, Hanson DL, Jones JL, et al. Viral load as an independent risk factor for opportunistic infections in HIV-infected adults and adolescents. AIDS. 2001;15(14):1831-1836. [pmid: 11579245].
92 Galetto-Lacour A, Yerly S, Perneger TV, et al. Prognostic value of viremia in patients with long-standing human immunodeficiency virus infection. Swiss HIV Cohort Study Group. J Infect Dis. 1996;173(6):1388-1393. [pmid: 8648210].
93 Phair JP, Mellors JWA, Detels RB, et al. Virologic and immunologic values allowing safe deferral of antiretroviral therapy. AIDS. 2002;16(18):2455-2459. [pmid: 12461420].
94 Mellors JW, Kingsley LA, Rinaldo CR Jr, et al. Quantitation of HIV-1 RNA in plasma predicts outcome after seroconversion. Ann Intern Med. 1995;122(8):573-579. [pmid: 7887550].
95 Sabin CA, Devereux H, Phillips AN, et al. Immune markers and viral load after HIV-1 seroconversion as predictors of disease progression in a cohort of haemophilic men. AIDS. 1998;12(11):1347-1352. [pmid: 9708415].
96 Lefrere JJ, Roudot-Thoraval F, Mariotti M, et al. The risk of disease progression is determined during the first year of human immunodeficiency virus type 1 infection. J Infect Dis. 1998;177(6):1541-1548. [pmid: 9607831].
97 Gandhi M, Bacchetti P, Miotti P, et al. Does patient sex affect human immunodeficiency virus levels?. Clin Infect Dis. 2002;35:313-322. [pmid: 12115098].
98 Farzadegan H, Hoover DR, Astemborski J, et al. Sex differences in HIV-1 viral load and progression to AIDS. Lancet. 1998;352(9139):1510-1514. [pmid: 9820299].
99 Sterling TR, Vlahov D, Astemborski J, et al. Initial plasma HIV-1 RNA levels and progression to AIDS in women and men. N Engl J Med. 2001;344(10):720-725. [pmid: 11236775].
100 Junghans C, Ledergerber B, Chan P, et al. Sex differences in HIV-1 viral load and progression to AIDS. Swiss HIV Cohort Study. Lancet. 1999;353(9152):589. [pmid: 10029004].
101 Babiker AG, Peto T, Porter K, et al. Age as a determinant of survival in HIV infection. J Clin Epidemiol. 2001;54:S16-S21. [pmid: 11750205].
102 Vella S, Giuliano M, Floridia M, et al. Effect of sex, age and transmission category on the progression to AIDS and survival of zidovudine-treated symptomatic patients. AIDS. 1995;9(1):51-56. [pmid: 7893441].
103 Chaisson RE, Keruly JC, Moore RD. Race, sex, drug use, and progression of human immunodeficiency virus disease. N Engl J Med. 1995;333:751-756. [pmid: 7643881].
104 Melnick SL, Sherer R, Louis TA, et al. Survival and disease progression according to gender of patients with HIV infection. The Terry Beirn Community Programs for Clinical Research on AIDS. JAMA. 1994;272(24):1915-1921. [pmid: 7990243].
105 Currier JS, Spino C, Grimes J, et al. Differences between women and men in adverse events and CD4+ responses to nucleoside analogue therapy for HIV infection. The Aids Clinical Trials Group 175 Team. J Acquir Immune Defic Syndr. 2000;24(4):316-324. [pmid: 11015147].
106 Mocroft A, Madge S, Johnson AM, et al. A comparison of exposure groups in the EuroSIDA study: starting highly active antiretroviral therapy (HAART), response to HAART, and survival. J Acquir Immune Defic Syndr. 1999;22(4):369-378. [pmid: 10634199].
107 Smith DK, Gwinn M, Selik RM, et al. HIV/AIDS among African Americans: progress or progression?. AIDS. 2000;14(9):1237-1248. [pmid: 10894289].
108 French R, Brocklehurst P. The effect of pregnancy on survival in women infected with HIV: a systematic review of the literature and meta-analysis. Br J Obstet Gynaecol. 1998;105(8):827-835. [pmid: 9746374].
109 Miguez MJ, Shor-Posner G, Morales G, et al. HIV treatment in drug abusers: impact of alcohol use. Addict Biol. 2003;8(1):33-37. [pmid: 12745413].
110 Kaslow RA, Blackwelder WC, Ostrow DG, et al. No evidence for a role of alcohol or other psychoactive drugs in accelerating immunodeficiency in HIV-1-positive individuals. A report from the Multicenter AIDS Cohort Study. JAMA. 1989;261(23):3424-3429. [pmid: 2524608].
111 Selwyn PA, Alcabes P, Hartel D, et al. Clinical manifestations and predictors of disease progression in drug users with human immunodeficiency virus infection. N Engl J Med. 1992;327(24):1697-1703. [pmid: 1359411].
112 Katz MH, Hsu L, Lingo M, et al. Impact of socioeconomic status on survival with AIDS. Am J Epidemiol. 1998;148:282-291. [pmid: 9690366].
113 Hogg RS, Strathdee SA, Craib KJP, et al. Lower socioeconomic status and shorter survival folowing HIV infection. Lancet. 1994;344:1120-1124. [pmid: 7934494].
114 Schechter MT, Hogg RS, Aylward B, et al. Higher socioeconomic status is associated with slower progression of HIV infection independent of access to health care. Journal of Clinical Epidemiology. 1994;47:59-67. [pmid: 7904296].
115 McFarland W, Chen S, Hsu L, et al. Low socioeconomic status is associated with a higher rate of death in the era of highly active antiretroviral therapy, San Francisco. J Acquir Immune Defic Syndr. 2003;33:96-103. [pmid: 12792361].
116 Golub ET, Astemborski JA, Hoover DR, et al. Psychological distress and progression to AIDS in a cohort of injection drug users. J Acquir Immune Defic Syndr. 2003;32(4):429-434. [pmid: 12640202].
117 Lyketsos CG, Hoover DR, Guccione M, et al. Depressive symptoms as predictors of medical outcomes in HIV infection. Multicenter AIDS Cohort Study. JAMA. 1993;270(21):2563-2567. [pmid: 7901432].
118 Ickovics JR, Hamburger ME, Vlahov D, et al. Mortality, CD4 cell count decline, and depressive symptoms among HIV-seropositive women: longitudinal analysis from the HIV Epidemiology Research Study. JAMA. 2001;285(11):1466-1474. [pmid: 11255423].
119 Jacobson DL, Wu AW, Feinberg J, et al. Health-related quality of life predicts survival, cytomegalovirus disease, and study retention in clinical trial participants with advanced HIV disease. Journal of Clinical Epidemiology. 2003;56(9):874-879. [pmid: 14505773].
120 Ioannidis JPA. Effects of CCR5-D32, CCR2-641, and SDF-1 3′ A alleles on HIV-1 disease progression: an international meta-analysis of individual patient data. Ann Intern Med. 2001;135:782-795. [pmid: 11694103].
121 Nolan D, Gaudieri S, John M, et al. Impact of host genetics on HIV disease progression and treatment: new conflicts on an ancient battleground. AIDS. 2004;18(9):1231-1240. [pmid: 15362655].
122 de Roda Husman AM, Koot M, Cornelissen M, et al. Association between CCR5 genotype and the clinical course of HIV-1 infection. Ann Intern Med. 1997;127(10):882-890. [pmid: 9382366].
123 Lathey JL, Tierney C, Chang SY, et al. Associations of CCR5, CCR2, and stromal cell-derived factor 1 genotypes with human immunodeficiency virus disease progression in patients receiving nucleoside therapy. J Infect Dis. 2001;184(11):1402-1411. [pmid: 11709782].
124 Marmor M, Sheppard HW, Donnell D, et al. Homozygous and heterozygous CCR5-Delta32 genotypes are associated with resistance to HIV infection. J Acquir Immune Defic Syndr. 2001;27(5):472-481. [pmid: 11511825].
125 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Alexandria, Virginia: International Medical Publishing; 1996.
126 Centers for Disease Control and Prevention. Revised guidelines for HIV counseling, testing, and referral. Morb Mortal Wkly Rep. 2001;50(RR-19):1-57.
127 Ahuja TS, Zingman B, Glicklich D. Long-term survival in an HIV-infected renal transplant recipient. Am J Nephrol. 1997;17(5):480-482. [pmid: 9382173].
128 Greub G, Ledergerber B, Battegay M, et al. Clinical progression, survival, and immune recovery during antiretroviral therapy in patients with HIV-1 and hepatitis C virus coinfection: the Swiss HIV Cohort Study. Lancet. 2000;356(9244):1800-1805. [pmid: 11117912].
129 De Luca A, Bugarini R, Lepri AC, et al. Coinfection with hepatitis viruses and outcome of initial antiretroviral regimens in previously naive HIV-infected subjects. Arch Intern Med. 2002;162(18):2125-2132. [pmid: 12374521].
130 Sulkowski MS, Moore RD, Mehta SH, et al. Hepatitis C and progression of HIV disease. JAMA. 2002;288(2):199-206. [pmid: 12095384].
131 Thio CL, Seaberg EC, Skolasky R Jr, et al. HIV-1, hepatitis B virus, and risk of liver-related mortality in the Multicenter Cohort Study (MACS). Lancet. 2002;360(9349):1921-1926. [pmid: 12493258].
132 Thio CL. Hepatitis B in the Human Immunodeficiency Virus-Infected Patient: Epidemiology, Natural History, and Treatment. Semin Liver Dis. 2003;23(2):125-136. [pmid: 12800066].
133 Perinbasekar S, Brod-Miller C, Pal S, et al. Predictors of survival in HIV-infected patients on hemodialysis. Am J Nephrol. 1996;16:280-286. [pmid: 8739279].
134 Feinfeld DA, Kaplan R, Dressler R, et al. Survival of human immunodeficiency virus-infected patients on maintenance dialysis. Clin Nephrol. 1989;32:221-224. [pmid: 2582646].
135 Kottilil S, Polis MA, Kovacs JA. HIV infection, hepatitis C infection, and HAART. JAMA. 2004;292:243-250. [pmid: 15249574].
136 Macias J, Castellano V, Merchante N, et al. Effect of antiretroviral drugs on liver fibrosis in HIV-infected patients with chronic hepatitis C: harmful impact of nevirapine. AIDS. 2004;18(5):767-774. [pmid: 15075511].
137 Ena J, Amador C, Benito C, et al. Risk and determinants of developing severe liver toxicity during therapy with nevirapine-and efavirenz-containing regimens in HIV-infected patients. Int J STD AIDS. 2003;14(11):776-781. [pmid: 14624743].
138 Livry C, Binquet C, Sgro C, et al. Acute liver enzyme elevations in HIV-1-infected patients. HIV Clin Trials. 2003;4(6):400-410. [pmid: 14628283].
139 Sulkowski MS. Hepatotoxicity Associated with Antiretroviral Therapy Containing HIV-1 Protease Inhibitors. Sem Liver Dis. 2003;23(2):183-194.
140 Sulkowski MS, Thomas DL, Mehta SH, et al. Hepatotoxicity associated with nevirapine or efavirenz-containing antiretroviral therapy: role of hepatitis C and B infections. Hepatology. 2002;35(1):182-189. [pmid: 11786975].
141 Dieterich DT, Robinson PA, Love J, et al. Drug-induced liver injury associated with the use of nonnucleoside reverse-transcriptase inhibitors. Clin Infect Dis. 2004;38(Suppl 2):S80-89. [pmid: 14986279].
142 Centers for Disease Control and Prevention. Updated U.S. Public Health Service guidelines for the management of occupational exposures to HBV, HCV, and HIV and recommendations for postexposure prophylaxis. Morb Mortal Wkly Rep. 2001;50(RR-11):1-52.
143 Bock PJ, Markovitz DM. Infection with HIV-2. AIDS. 2001;15(suppl 5):S35-S45. [pmid: 11816173].
144 O'Brien TR, George JR, Holmberg SD. Human immunodeficiency virus type 2 infection in the United States. Epidemiology, diagnosis, and public health implications. JAMA. 1992;267(20):2775-2779. [pmid: 1578597].
145 Centers for Disease Control and Prevention. Current trends update: serologic testing for antibody to human immunodeficiency virus. Morb Mortal Wkly Rep. 1988;36(52):833-845.
146 Centers for Disease Control and Prevention. Interpretation and use of the Western blot assay for serodiagnosis of human immunodeficieny virus type 1 infections. Morb Mortal Wkly Rep. 1989;38(S-7):1-7.
147 Clotet Ba, Raffi Fb, Cooper Dc, et al. Clinical management of treatment-experienced, HIV-infected patients with the fusion inhibitor enfuvirtide: consensus recommendations. AIDS. 2004;18(8):1137-1146. [pmid: 15166529].
148 Lazelari JP, Henry K, O'Hearn M, et al. Enfuvirtide, an HIV-1 fusion inhibitor, for drug-resistant HIV infection in North and South America. N Engl J Med. 2003;348:2175-2185. [pmid: 12637625].
149 Lazzarin A, Clotet B, Cooper D, et al. Efficacy of enfuvirtide in patients infected with drug-resistant HIV-1 in Europe and Australia. N Engl J Med. 2003;348(22):2186-2195. [pmid: 12773645].
150 Lawrence J, Mayers DL, Hullsiek KH, et al. Structured treatment interruption in patients with multidrug-resistant human immunodeficiency virus. N Engl J Med. 2003;349(9):837-846. [pmid: 12944569].
151 Lori F, Lisziewicz J. Structured Treatment Interruptions for the Management of HIV Infection. JAMA. 2001;286(23):2981-2987. [pmid: 11743839].
152 Gulick RM, Mellors JW, Havlir D, et al. Simultaneous vs sequential initiation of therapy with indinavir, zidovudine, and lamivudine for HIV-1 infection: 100-week follow-up. JAMA. 1998;280(1):35-41. [pmid: 9660361].
153 Bucher HC, Kofler A, Nuesch R, et al. Meta-analysis of randomized controlled trials of simplified versus continued protease inhibitor-based antiretroviral therapy in HIV-1-infected patients. AIDS. 2003;17:2451-2459. [pmid: 14600516].
154 Pialoux G, Raffi F, Brun-Vezinet F, et al. A randomized trial of three maintenance regimens given after three months of induction therapy with zidovudine, lamivudine, and indinavir in previously untreated HIV-1-infected patients. Trilege Agence Nationale de Recherches sur le SIDA 072 Study Team. N Engl J Med. 1998;339(18):1269-1276. [pmid: 9791142].
155 Rutherford GW, Feldman KA, Kennedy GE. Three- or four- versus two-drug antiretroviral maintenance regimens for HIV infection (Cochrane Review). The Cochrane Library. Chichester, UK: John Wiley & Sons, Ltd.; 2003.
156 Reijers MH, Weverling GJ, Jurriaans S, et al. The ADAM study continued: maintenance therapy after 50 weeks of induction therapy. AIDS. 2001;15(1):129-131. [pmid: 11192858].
157 Reijers MH, Weverling GJ, Jurriaans S, et al. Maintenance therapy after quadruple induction therapy in HIV-1 infected individuals: Amsterdam Duration of Antiretroviral Medication (ADAM) study. Lancet. 1998;352(9123):185-190. [pmid: 9683207].
158 Flandre P, Raffi F, Descamps D, et al. Final analysis of the Trilege induction-maintenance trial: results at 18 months. AIDS. 2002;16(4):561-568. [pmid: 11872999].
159 Havlir DV, Marschner IC, Hirsch MS, et al. Maintenance antiretroviral therapies in HIV infected patients with undetectable plasma HIV RNA after triple-drug therapy. AIDS Clinical Trials Group Study 343 Team. N Engl J Med. 1998;339(18):1261-1268. [pmid: 9791141].
160 Blanckenberg DH, Wood R, Horban A, et al. Evaluation of nevirapine and/or hydroxyurea with nucleoside reverse transcriptase inhibitors in treatment-naive HIV-1-infected subjects. AIDS. 2004;18(4):631-640. [pmid: 15090768].
161 Davey RT Jr, Murphy RL, Graziano FM, et al. Immunologic and virologic effects of subcutaneous interleukin 2 in combination with antiretroviral therapy: A randomized controlled trial. JAMA. 2000;284(2):183-189. [pmid: 10889591].
162 Ioannidis JP, Collier AC, Cooper DA, et al. Clinical efficacy of high-dose acyclovir in patients with human immunodeficiency virus infection: a meta-analysis of randomized individual patient data. J Infect Dis. 1998;178(2):349-359. [pmid: 9697714].
163 Patton LL, Bonito AJ, Shugars DA. A systematic review of the effectiveness of antifungal drugs for the prevention and treatment of oropharyngeal candidiasis in HIV-positive patients. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2001;92(2):170-179. [pmid: 11505264].
164 Richman DD, Morton SC, Wrin T, et al. The prevalence of antiretroviral drug resistance in the United States. AIDS. 2004;18:1393-1401. [pmid: 15199315].
165 Weinstock H, Respess R, Heneine W, et al. Prevalence of mutations associated with reduced antiretroviral drug susceptibility among human immunodeficiency virus type 1 seroconverters in the United States, 1993-1998. J Infect Dis. 2000;182(1):330-333. [pmid: 10882618].
166 Simon V, Vanderhoeven J, Hurley A, et al. Evolving patterns of HIV-1 resistance to antiretroviral agents in newly infected individuals. AIDS. 2002;16(11):1511-1519. [pmid: 12131189].
167 Boden D, Hurley A, Zhang L, et al. HIV-1 drug resistance in newly infected individuals. JAMA. 1999;282(12):1135-1141. [pmid: 10501116].
168 Little SJ, Daar ES, D'Aquila RT, et al. Reduced antiretroviral drug susceptibility among patients with primary HIV infection. JAMA. 1999;282(12):1142-1149. [pmid: 10501117].
169 Little SJ, Holte S, Routy JP, et al. Antiretroviral-drug resistance among patients recently infected with HIV. N Engl J Med. 2002;347(6):385-394. [pmid: 12167680].
170 Wegner SA, Wallace MR, Aronson NE, et al. Long-term efficacy of routine access to antiretroviral-resistance testing in HIV type 1-infected patients: results of the clinical efficacy of resistance testing trial. Clin Infect Dis. 2004;38(5):723-730. [pmid: 14986258].
171 Torre D, Tambini R. Antiretroviral drug resistance testing in patients with HIV-1 infection: a meta-analysis study. HIV Clin Trials. 2002;3(1):1-8. [pmid: 11819179].
172 Durant J, Clevenbergh P, Halfon P, et al. Drug-resistance genotyping in HIV-1 therapy: the VIRADAPT randomised controlled trial. Lancet. 1999;353(9171):2195-2199. [pmid: 10392984].
173 Hirsch MS, Brun-Vezinet F, D'Aquila RT, et al. Antiretroviral drug resistance testing in adult HIV-1 infection: recommendations of an International AIDS Society-USA Panel. JAMA. 2000;283(18):2417-2426. [pmid: 10815085].
174 Avanti Steering Committee. Analysis of HIV-1 clinical trials: statistical magic? Lancet. 1999;353(9169):2061–2064.
175 Centers for Disease Control and Prevention. Report of the NIH panel to define principles of therapy of HIV infection and guidelines for the use of antiretroviral agents in HIV-infected adults and adolescents. Morb Mortal Wkly Rep. 1998;47(No. RR-5):1-82.
176 Harris RP, Helfand M, Woolf SH, et al. Current methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
177 Weinstock H, Dale M, Gwinn M, et al. HIV seroincidence among patients at clinics for sexually transmitted diseases in nine cities in the United States. J Acquir Immune Defic Syndr. 2002;29(5):478-483. [pmid: 11981364].
178 Centers for Disease Control and Prevention. HIV Prevalence Trends in Selected Populations in the United States: Results from National Serosurveillance, 1993-1997. Atlanta, Georgia: Centers for Disease Control and Prevention; 2001.
179 Harawa NT, Douglas J, McFarland W, et al. Trends in HIV prevalence among public sexually transmitted disease clinic attendees in the Western region of the United States (1989-1999). J Acquir Immune Defic Syndr. 2004;37:1206-1215. [pmid: 15319682].
180 Catania JA, Osmond D, Stall RD, et al. The continuing HIV epidemic among men who have sex with men. Am J Public Health. 2001;91(6):907-914. [pmid: 11392933]. [pmcid: 1446467].
181 Holmberg SD. The estimated prevalence and incidence of HIV in 96 large US metropolitan areas. Am J Public Health. 1996;86(5):642-654. [pmid: 8629714]. [pmcid: 1380471].
182 Valleroy LA, MacKellar DA, Karon JM, et al. HIV prevalence and associated risks in young men who have sex with men. Young Men's Survey Study Group. JAMA. 2000;284(2):198-204. [pmid: 10889593].
183 Des Jarlais DC, Perlis T, Friedman SR, et al. Declining seroprevalence in a very large HIV epidemic: injecting drug users in New York City, 1991 to 1996. Am J Public Health. 1998;88(12):1801-1806. [pmid: 9842377]. [pmcid: 1509056].
184 Des Jarlais DC, Marmor M, Paone D, et al. HIV incidence among injecting drug users in New York City syringe-exchange programmes. Lancet. 1996;348(9033):987-991. [pmid: 8855855].
185 Prevots DR, Allen DM, Lehman JS, et al. Trends in human immunodeficiency virus seroprevalence among injection drug users entering drug treatment centers, United States, 1988-1993. Am J Epidemiol. 1996;143(7):733-742. [pmid: 8651236].
186 Tortu S, McCoy HV, Beardsley M, et al. Predictors of HIV infection among women drug users in New York and Miami. Women & Health. 1998;27(12):191-204.
187 Morse EV, Simon PM, Osofsky HJ, et al. The male street prostitute: a vector for transmission of HIV infection into the heterosexual world. Soc Sci Med. 1991;32(5):535-539. [pmid: 2017720].
188 Tabet SR, Palmer DL, Wiese WH, et al. Seroprevalence of HIV-1 and hepatitis B and C in prostitutes in Albuquerque, New Mexico. Am J Public Health. 1992;82(8):1151-1154. [pmid: 1636841]. [pmcid: 1695759].
189 Elifson KW, Boles J, Sweat M. Risk factors associated with HIV infection among male prostitutes. Am J Public Health. 1993;83(1):79-83. [pmid: 8417612]. [pmcid: 1694529].
190 Elifson KW, Boles J, Darrow WW, et al. HIV seroprevalence and risk factors among clients of female and male prostitutes. J Acquir Immune Defic Syndr Hum Retrovirol. 1999;20(2):195-200. [pmid: 10048908].
191 Day S, Ward H, Perrotta L. Prostitution and risk of HIV: male partners of female prostitutes. BMJ. 1993;307(6900):359-361. [pmid: 8374418]. [pmcid: 1678199].
192 Lansky A, Nakashima AK, Jones JL. Risk behaviors related to heterosexual transmission from HIV-infected persons. Supplement to HIV/AIDS Surveillance Study Group. Sex Transm Dis. 2000;27(8):483-489. [pmid: 10987457].
193 Peterman TA, Todd KA, Mupanduki I. Opportunities for targeting publicly funded human immunodeficiency virus counseling and testing. J Acquir Immune Defic Syndr Hum Retrovirol. 1996;12(1):69-74. [pmid: 8624764].
194 Lynch DA, Krantz S, Russell JM, et al. HIV infection: a retrospective analysis of adolescent high-risk behaviors. Journal of Pediatric Health Care. 2000;14(1):20-25. [pmid: 11141822].
195 Huba GJ, Melchior LA, Panter AT, et al. Risk factors and characteristics of youth living with, or at high risk for, HIV. AIDS Educ Prev. 2000;12(6):557-575. [pmid: 11220507].
196 Heffernan R, Chiasson MA, Sackoff JE. HIV risk behaviors among adolescents at a sexually transmitted disease clinic in New York City. J Adolesc Health. 1996;18(6):429-434. [pmid: 8803735].
197 Allen DM, Lehman JS, Green TA, et al. HIV infection among homeless adults and runaway youth, United States, 1989-1992. Field Services Branch. AIDS. 1994;8(11):1593-1598. [pmid: 7848596].
198 Sweeney P, Lindegren ML, Buehler JW, et al. Teenagers at risk of human immunodeficiency virus type 1 infection. Results from seroprevalence surveys in the United States. Arch Pediatr Adolesc Med. 1995;149(5):521-528. [pmid: 7735404].
199 Miller CL, Tyndall M, Spittal P, et al. HIV incidence and associated risk factors among young injection drug users. AIDS. 2002;16(3):491-493. [pmid: 11834965].
200 Murphy EL, Busch MP, Tong M, et al. A prospective study of the risk of transfusion-acquired viral infections. Transfusion Medicine. 1998;8(3):173-178. [pmid: 9800288].
201 Prati D, Capelli C, Rebulla P, et al. The current risk of retroviral infections transmitted by transfusion in patients who have undergone multiple transfusions. Cooleycare Cooperative Group. Arch Intern Med. 1998;158(14):1566-1569. [pmid: 9679798].
202 Lee LM, Fleming PL. Trends in human immunodeficiency virus diagnoses among women in the United States, 1994-1998. J Am Med Womens Assoc. 2001;56(3):94-99. [pmid: 11506153].
203 Weinhardt LS, Kelly JA, Brondino MJ, et al. HIV transmisison risk behavior among men and women living with HIV in 4 cities in the United States. J Acquir Immune Defic Syndr. 2004;36(5):1057-1066. [pmid: 15247559].
204 Centers for Disease Control and Prevention. Prevalence of risk behaviors for HIV infection among adults - United States, 1997. Morb Mortal Wkly Rep. 2001;50(14):262-265.
205 Abma JC, Sonenstein FL. Sexual activity and contraceptive practices among teenagers in the United States, 1988 and 1995. Vital Health Stat 23. 2001(21):1–79
206 Sonenstein FL, Ku L, Lindberg L, et al. Changes in Sexual Behavior and Condom Use among Teenaged Males: 1988 to 1995. Am J Public Health. 1998;88(6):956-959. [pmid: 9618629]. [pmcid: 1508224].
207 Centers for Disease Control and Prevention. HIV/AIDS Special Surveillance Report. HIV Testing Survey, 2000. 2003;1(No. 1):1-27.
208 Rawitscher LA, Saitz R, Friedman LS. Adolescents' preferences regarding human immunodeficiency virus (HIV)-related physician counseling and HIV testing. Pediatrics. 1995;96:52-58. [pmid: 7596723].
209 Gerbert B, Macguire BT, Coates TJ. Are patients talking to their physicians about AIDS?. Am J Public Health. 1990;80:467-468. [pmid: 2316771]. [pmcid: 1404581].
210 Gerbert B, Bronstone A, McPhee S, et al. Development and testing of an HIV-risk screening instrument for use in health care settings. Am J Prev Med. 1998;15(2):103-113. [pmid: 9713665].
211 Gerbert B, Brown B, Volberding P, et al. Physicians' transmission prevention assessment and counseling practices with their HIV positive patients. AIDS Educ Prev. 1999;11(4):307-320. [pmid: 10494355].
212 Klein D, Hurley LB, Merrill DP, et al. Review of medical encounters in the 5 years before a diagnosis of HIV-1 infection: implications for early detection. J Acquir Immune Defic Syndr. 2003;32(2):143-152. [pmid: 12571523].
213 Liddicoat RV, Horton NJ, Urban R, et al. Assessing missed opportunities for HIV testing in medical settings. J Gen Intern Med. 2004;19(4):349-356. [pmid: 15061744]. [pmcid: 1492189].
214 Chen Z, Branson B, Ballenger A, et al. Risk assessment to improve targeting of HIV counseling and testing services of STD clinic patients. Sex Transm Dis. 1998;25(10):539-543. [pmid: 9858350].
215 Kelen GD, Hexter DA, Hansen KN, et al. Feasibility of an emergency department-based, risk-targeted voluntary HIV screening program. Ann Emerg Med. 1996;27(6):687-692. [pmid: 8644953].
216 Kirkland KB, Meriwether RA, MacKenzie WR, et al. Clinician judgement as a tool for targeting HIV counseling and testing in North Carolina state mental hospitals, 1994. AIDS Patient Care STDS. 1999;13(8):473-479. [pmid: 10800526].
217 Groseclose SL, Erickson B, Quinn TC, et al. Characterization of patients accepting and refusing routine, voluntary HIV antibody testing in public sexually transmitted disease clinics. Sex Transm Dis. 1994;21(1):31-35. [pmid: 8140486].
218 Erickson B, Wasserheit JN, Rompalo AM, et al. Routine voluntary HIV screening in STD clinic clients: characterization of infected clients. Sex Transm Dis. 1990;17(4):194-199. [pmid: 2264008].
219 Kassler WJ, Zenilman JM, Erickson B, et al. Seroconversion in patients attending sexually transmitted disease clinics. AIDS. 1994;8:351-355. [pmid: 8031513].
220 Alpert PL, Shuter J, DeShaw MG, et al. Factors associated with unrecognized HIV-1 infection in an inner-city emergency department. Ann Emerg Med. 1996;28(2):159-164. [pmid: 8759579].
221 D'Angelo LJ, Getson PR, Luban NL, et al. Human immunodeficiency virus infection in urban adolescents: can we predict who is at risk?. Pediatrics. 1991;88(5):982-986. [pmid: 1945639].
222 Harris RL, Boisaubin EV, Salyer PD, et al. Evaluation of a hospital admission HIV antibody voluntary screening program. Infect Control Hosp Epidemiol. 1990;11(12):628-634. [pmid: 2125612].
223 Asch SM, London AS, Barnes PF, et al. Testing for human immunodeficiency virus infection among tuberculosis patients in Los Angeles. Am J Respir Crit Care Med. 1997;155(1):378-381. [pmid: 9001340].
224 Theuer CP, Hopewell PC, Elias D, et al. Human immunodeficiency virus infection in tuberculosis patients. J Infect Dis. 1990;162(1):8-12. [pmid: 1972384].
225 Centers for Disease Control and Prevention. Voluntary HIV testing as part of routine medical care - Massachusetts, 2002. Morb Mortal Wkly Rep. 2004;53(24):523-526.
226 Centers for Disease Control and Prevention. Routinely recommended HIV testing at an urban urgent-care clinic—Atlanta, Georgia, 2000. Morb Mortal Wkly Rep. 2001;50(25):538-541.
227 Walensky RP, Losina E, Steger-Craven KA, et al. Identifying undiagnosed human immunodeficiency virus: the yield of routine, voluntary inpatient testing. Arch Intern Med. 2002;162(8):887-892. [pmid: 11966339].
228 Goggin MA, Davidson AJ, Cantril SV, et al. The extent of undiagnosed HIV infection among emergency department patients: results of a blinded seroprevalence survey and a pilot HIV testing program. J Emerg Med. 2000;19(1):13-19. [pmid: 10863112].
229 Jones JL, Hutto P, Meyer P, et al. HIV seroprevalence and reasons for refusing and accepting HIV testing. Sex Transm Dis. 1993;20(6):334-337. [pmid: 8108756].
230 Reardon J, Warren N, Keilch R, et al. Are HIV-infected injection drug users taking HIV tests?. Am J Public Health. 1993;83(10):1414-1417. [pmid: 8214230]. [pmcid: 1694836].
231 Weinstock H, Dale M, Linley L, et al. Unrecognized HIV infection among patients attending sexually transmitted disease clinics. Am J Public Health. 2002;92(2):280-283. [pmid: 11818306]. [pmcid: 1447057].
232 Golden MR. HIV partner notification: a neglected prevention intervention. Sex Transm Dis. 2002;29(8):472-475. [pmid: 12172532].
233 Fenton KA, French R, Giesecke J, et al. An evaluation of partner notification for HIV infection in genitourinary medicine clinics in England. AIDS. 1998;12(1):95-102. [pmid: 9456259].
234 Macke BA, Maher JE. Partner notification in the United States: An evidence-based review. Am J Prev Med. 1999;17(3):230-242. [pmid: 10987639].
235 Centers for Disease Control and Prevention. Partner counseling and referral services to identify persons with undiagnosed HIV—North Carolina, 2001. Morb Mortal Wkly Rep. 2003;52(48):1181-1184.
236 Centers for Disease Control and Prevention. Interpretation and use of the western blot assay for serodiagnosis of human immunodeficiency virus type 1 infections. JAMA. 1989;262(24):3395-3397. [pmid: 2685380].
237 Centers for Disease Control and Prevention. Update: serologic testing for HIV-1 antibody—United States, 1988 and 1989. Morb Mortal Wkly Rep. 1990;39(22):380-383.
238 Phillips KA. The use of meta-analysis in technology assessment: a meta-analysis of the enzyme immunosorbent assay human immunodeficiency virus antibody test. J Clin Epidemiol. 1991;44(9):925-931. [pmid: 1832441].
239 MacDonald KL, Jackson JB, Bowman RJ, et al. Performance characteristics of serologic tests for human immunodeficiency virus type 1 (HIV-1) antibody among Minnesota blood donors. Public health and clinical implications. Ann Intern Med. 1989;110(8):617-621. [pmid: 2648922].
240 Weber B, Moshtaghi-Boronjeni M, Brunner M, et al. Evaluation of the reliability of 6 current anti-HIV-1/HIV-2 enzyme immunoassays. J Virol Methods. 1995;55(1):97-104. [pmid: 8576312].
241 McAlpine L, Gandhi J, Parry JV, et al. Thirteen current anti-HIV-1/HIV-2 enzyme immunoassays: how accurate are they?. Journal of Medical Virology. 1994;42:115-118. [pmid: 8158104].
242 Celum CL, Coombs RW, Lafferty W, et al. Indeterminate human immunodeficiency virus type 1 western blots: seroconversion risk, specificity of supplemental tests, and an algorithm for evaluation. J Infect Dis. 1991;164(4):656-664. [pmid: 1894929].
243 Mylonakis E, Paliou M, Lally M, et al. Laboratory testing for infection with the human immunodeficiency virus: established and novel approaches. Am J Med. 2000;109(7):568-576. [pmid: 11063959].
244 Busch MP, Kleinman SH, Williams AE, et al. Frequency of human immunodeficiency virus (HIV) infection among contemporary anti-HIV-1 and anti-HIV-1/2 supplemental test-indeterminate blood donors. The Retrovirus Epidemiology Donor Study. Transfusion. 1996;36(1):37-44. [pmid: 8607151].
245 Schopper D, Vercauteren G. Testing for HIV at home: what are the issues?. AIDS. 1996;10(13):1455-1465. [pmid: 8931779].
246 Branson BM. Point-of-care rapid tests for HIV antibodies. Journal of Laboratory Medicine. 2003;27(7/8):288-295.
247 Donovan BJ, Rublein JC, Leone PA, et al. HIV infection: point-of-care testing. Ann Pharmacother. 2004;38(4):670-676. [pmid: 14990775].
248 RevealTM Rapid HIV-1 Antibody Test (package insert; #FDAINS0065). Halifax, Nova Scotia, Canada: MedMira Laboratories, Inc.; rev. 0/1.
249 Uni-GoldTM Recombigen® HIV (package insert; #045–138). Bray, Ireland: Trinity Biotech Plc.; rev. 03/04.
250 OraQuick® Rapid HIV-1 Antibody Test (package insert; #3001–0951). Bethlehem, PA: OraSure Technologies, Inc.; rev. 10/03.
251 Centers for Disease Control and Prevention. Protocols for confirmation of reactive rapid HIV tests. Morb Mortal Wkly Rep. 2004;53(10):221-222.
252 Bulterys M, Jamieson DJ, O'Sullivan MJ, et al. Rapid HIV-1 testing during labor. JAMA. 2004;292(2):219-223. [pmid: 15249571].
253 Reynolds SJ, Ndongala LM, Luo CC, et al. Evaluation of a rapid test for the detection of antibodies to human immunodeficiency virus type 1 and 2 in the setting of multiple transmitted viral subtypes. Int J STD AIDS. 2002;13(3):171-173. [pmid: 11860693].
254 O'Connell RJ, Merritt TM, Malia JA, et al. Performance of the OraQuick rapid antibody test for diagnosis of human immunodeficiency virus type 1 infection in patients with various levels of exposure to highly active antiretroviral therapy. J Clin Microbiol. 2003;41(5):2153-2155. [pmid: 12734265]. [pmcid: 154669].
255 Giles RE, Perry KR, Parry JV. Simple/rapid test devices for anti-HIV screening: do they come up to the mark?. J Med Virol. 1999;59(1):104-109. [pmid: 10440816].
256 Kassler WJ, Haley C, Jones WK, et al. Performance of a rapid, on-site human immunodeficiency virus antibody assay in a public health setting. J Clin Microbiol. 1995;33(11):2899-2902. [pmid: 8576342]. [pmcid: 228603].
257 Malone JD, Smith ES, Sheffield J, et al. Comparative evaluation of six rapid serological tests for HIV-1 antibody. J Acquir Immune Defic Syndr. 1993;6(2):115-119. [pmid: 8433277].
258 Stetler HC, Granade TC, Nunez CA, et al. Field evaluation of rapid HIV serologic tests for screening and confirming HIV-1 infection in Honduras. AIDS. 1997;11(3):369-375. [pmid: 9147429].
259 Gallo D, George JR, Fitchen JH, et al. Evaluation of a system using oral mucosal transudate for HIV-1 antibody screening and confirmatory testing. OraSure HIV Clinical Trials Group. JAMA. 1997;277(3):254-258. [pmid: 9005276].
260 Granade TC, Phillips SK, Parekh B, et al. Detection of Antibodies to Human Immunodeficiency Virus Type 1 in Oral Fluids: A Large-Scale Evaluation of Immunoassay Performance. Clin Diagn Lab Immunol. 1998;5(2):171-175. [pmid: 9521138]. [pmcid: 121353].
261 World Health Organization. HIV assays: operational characteristics (phase I) - urine and oral fluid (saliva) specimens. January 2002. Available at: http://www.who.int/bct/Main_areas_of_work/BTS/HIV_Diagnostics/Evaluation_reports/Rep13Draft.pdf. Accessed July 20, 2004.
262 Martinez PD, Torres AR, de Lejarazu RO, et al. Human immunodeficiency virus antibody testing by enzyme-linked fluorescent and Western blot assays using serum, gingival-crevicula transudate, and urine samples. J Clin Microbiol. 1999;37(4):1100-1106. [pmid: 10074532]. [pmcid: 88655].
263 Desai S, Bates H, Michalski FJ. Detection of antibody to HIV-1 in urine. Lancet. 1991;337(8734):183-184. [pmid: 1670828].
264 Frank AP, Wandell MG, Headings MD, et al. Anonymous HIV testing using home collection and telemedicine counseling. A multicenter evaluation. Arch Intern Med. 1997;157(3):309-314. [pmid: 9040298].
265 Spielberg F, Critchlow C, Vittinghoff E, et al. Home collection for frequent HIV testing: acceptability of oral fluids, dried blood spots and telephone results. HIV Early Detection Study Group. AIDS. 2000;14(12):1819-1828. [pmid: 10985320].
266 Pilcher CD, McPherson JT, Leone PA, et al. Real-time, universal screening for acute HIV infection in a routine HIV counseling and testing population. JAMA. 2002;288:216-221. [pmid: 12095386].
267 Kaplan EH, Satten GA. Repeat screening for HIV: when to test and why. J Acquir Immune Defic Syndr. 2000;23(4):339-345. [pmid: 10836757].
268 Weinstock H, Sweeney S, Satten GA, et al. HIV seroincidence and risk factors among patients repeatedly tested for HIV attending sexually transmitted disease clinics in the United States, 1991 to 1996. STD Clinic HIV Seroincidence Study Group. J Acquir Immune Defic Syndr Hum Retrovirol. 1998;19(5):506-512. [pmid: 9859965].
269 McCusker J, Willis G, McDonald M, et al. Community-wide HIV counselling and testing in central Massachusetts: who is retested and does their behavior change?. J Community Health. 1996;21(1):11-22. [pmid: 8903580].
270 Fernyak SE, Page-Shafer K, Kellogg TA, et al. Risk behaviors and HIV incidence among repeat testers at publicly funded HIV testing sites in San Francisco. J Acquir Immune Defic Syndr. 2002;31(1):63-70. [pmid: 12352152].
271 Schwarcz SK, Spitters C, Ginsberg MM, et al. Predictors of Human Immunodeficiency Virus Counseling and Testing Among Sexually Transmitted Disease Clinic Patients. Sex Transm Dis. 1997;24(6):347-352. [pmid: 9243742].
272 Kleinman S, Busch MP, Hall L, et al. False-positive HIV-1 test results in a low-risk screening setting of voluntary blood donation. Retrovirus Epidemiology Donor Study. JAMA. 1998;280(12):1080-1085. [pmid: 9757856].
273 Mylonakis E, Paliou M, Greenbough TC, et al. Report of a false-positive HIV test result and the potential use of additional tests in establishing HIV serostatus. Arch Intern Med. 2000;160(15):2386-2388. [pmid: 10927739].
274 Wai CT, Tambyah PA. False-positive HIV-1 ELISA in patients with hepatitis B. Am J Med. 2002;112(9):737. [pmid: 12079718].
275 Sayre KR, Dodd RY, Tegtmeier G, et al. False-positive human immunodeficiency virus type 1 western blot tests in noninfected blood donors. Transfusion. 1996;36(1):45-52. [pmid: 8607152].
276 Centers for Disease Control and Prevention. Rapid HIV antibody testing during labor and delivery for women of unknown HIV status. Available at: http://www.cdc.gov/hiv/rapid_testing/materials/Labor&DeliveryRapidTesting.pdf. Accessed July 20, 2004.
277 Herek GM, Capitanio JP, Widaman KF. HIV-related stigma and knowledge in the United States: prevalence and trends, 1991-1999. Am J Public Health. 2002;92(3):371-377. [pmid: 11867313]. [pmcid: 1447082].
278 Centers for Disease Control and Prevention. HIV-related knowledge and stigma—United States, 2000. Morb Mortal Wkly Rep. 2000;49(47):1062-1064.
279 Gielen AC, O'Campo P, Faden RR, et al. Women's disclosure of HIV status: experiences of mistreatment and violence in an urban setting. Women Health. 1997;25(3):19-31. [pmid: 9273981].
280 Kilmarx PH, Hamers FF, Peterman TA. Living with HIV. Experiences and perspectives of HIV-infected sexually transmitted disease clinic patients after posttest counseling. Sex Transm Dis. 1998;25(1):28-37. [pmid: 9437782].
281 Rundell JR, Kyle KM, Brown GR, et al. Risk factors for suicide attempts in a human immunodeficiency virus screening program. Psychosomatics. 1992;33(1):24-27. [pmid: 1539099].
282 Marzuk PM, Tierney H, Tardiff K, et al. Increased risk of suicide in persons with AIDS. JAMA. 1988;259(9):1333-1337. [pmid: 3339837].
283 van Haastrecht HJ, Mientjes GH, van den Hoek AJ, et al. Death from suicide and overdose among drug injectors after disclosure of first HIV test result. AIDS. 1994;8(12):1721-1725. [pmid: 7888122].
284 Cote TR, Biggar RJ, Dannenberg AL. Risk of suicide among persons with AIDS. A national assessment. JAMA. 1992;268(15):2066-2068. [pmid: 1404744].
285 Dannenberg AL, McNeil JG, Brundage JF, et al. Suicide and HIV infection. Mortality follow-up of 4147 HIV-seropositive military service applicants. JAMA. 1996;276(21):1743-1746. [pmid: 8940323].
286 Chesney MA, Chambers DB, Taylor JM, et al. Coping effectiveness training for men living with HIV: results from a randomized clinical trial testing a group-based intervention. Psychosom Med. 2003;65(6):1038-1046. [pmid: 14645783].
287 Antoni MH, Cruess DG, Cruess S, et al. Cognitive-behavioral stress management intervention effects on anxiety, 24-hr urinary norepinephrine output, and T-cytotoxic/suppressor cells over time among symptomatic HIV-infected gay men. J Consult Clin Psychol. 2000;68(1):31-45. [pmid: 10710838].
288 Cruess DG, Antoni MH, Schneiderman N, et al. Cognitive-behavioral stress management increases free testosterone and decreases psychological distress in HIV-seropositive men. Health Psychol. 2000;19(1):12-20. [pmid: 10711583].
289 Kelly JA, Murphy DA, Bahr GR, et al. Outcome of cognitive-behavioral and support group brief therapies for depressed, HIV-infected persons. American Journal of Psychiatry. 1993;150:1679-1686. [pmid: 8214177].
290 Lutgendorf S, Antoni MH, Schneiderman N, et al. Psychosocial counseling to improve quality of life in HIV infection. Patient Educ Couns. 1994;24(3):217-235. [pmid: 7753716].
291 Perry S, Fishman B, Jacobsberg L, et al. Effectiveness of psychoeducational interventions in reducing emotional distress after human immunodeficiency virus antibody testing. Arch Gen Psychiatry. 1991;48(2):143-147. [pmid: 1989570].
292 Antoni MH. Psychosocial stressors and behavioral interventions in gay men with HIV infection. Int Rev Psychiatry. 1991;3(34):383-399.
293 North RL, Rothenberg KH. Partner notification and the threat of domestic violence against women with HIV infection. N Engl J Med. 1993;329(16):1194-1196. [pmid: 8377787].
294 Zierler S, Cunningham WE, Andersen R, et al. Violence victimization after HIV infection in a US probability sample of adult patients in primary care. Am J Public Health. 2000;90(2):208-215. [pmid: 10667181]. [pmcid: 1446146].
295 Gielen AC, McDonnell KA, Burke JG, et al. Women's lives after an HIV-positive diagnosis: disclosure and violence. Matern Child Health J. 2000;4(2):111-120. [pmid: 10994579].
296 Liebschutz JM, Feinman G, Sullivan L, et al. Physical and sexual abuse in women infected with the human immunodeficiency virus. Arch Intern Med. 2000;160:1659-1664. [pmid: 10847259].
297 Vlahov D, Wientge D, Moore J, et al. Violence among women with or at risk for HIV infection. AIDS Behav. 1998;2(1):53-60.
298 Koenig LJ, Moore J. Women, violence, and HIV: a critical evaluation with implications for HIV services. Matern Child Health J. 2000;4(2):103-109. [pmid: 10994578].
299 Cohen M, Deamant C, Barkan S, et al. Domestic violence and childhood sexual abuse in HIV-infected women and women at risk for HIV. Am J Public Health. 2000;90(4):560-565. [pmid: 10754970]. [pmcid: 1446192].
300 Kissinger PJ, Niccolai LM, Mangus M, et al. Partner notification for HIV and syphilis: effects on sexual behaviors and relationship stability. Sex Transm Dis. 2003;30(1):75-82. [pmid: 12514447].
301 Schnell DJ, Higgins DL, Wilson RM, et al. Men's disclosure of HIV test results to male primary sex partners. Am J Public Health. 1992;82(12):1675-1676. [pmid: 1456347]. [pmcid: 1694539].
302 Hoxworth T, Spencer NE, Peterman TA, et al. Changes in partnerships and HIV risk behaviors after partner notification. Sex Transm Dis. 2003;30(1):83-88. [pmid: 12514448].
303 Centers for Disease Control and Prevention. Number of persons tested for HIV—United States, 2002. Morb Mortal Wkly Rep. 2004;53(47):1110-1113.
304 Abma JC, Chandra A, Mosher W, et al. Fertility, family planning, and women's health: new data from the 1995 National Survey of Family Growth. Vital Health Stat 23. 1997;19:1-114. [pmid: 9201902].
305 Anderson JE, Carey JW, Taveras S. HIV testing among the general US population and persons at increased risk: information from national surveys, 1987-1996. Am J Public Health. 2000;90(7):1089-1095. [pmid: 10897187]. [pmcid: 1446310].
306 Kellerman SE, Lehman JS, Lansky A, et al. HIV testing within at-risk populations in the United States and the reasons for seeking or avoiding HIV testing. J Acquir Immune Defic Syndr. 2002;31(2):202-210. [pmid: 12394799].
307 Irwin KL, Valdiserri RO, Holmberg SD. The acceptability of voluntary HIV antibody testing in the United States: a decade of lessons learned. AIDS. 1996;10(14):1707-1717. [pmid: 8970692].
308 Maher JE, Peterson J, Hastings K, et al. Partner violence, partner notification, and women's decisions to have an HIV test. J Acquir Immune Defic Syndr. 2000;25:276-282. [pmid: 11115959].
309 Futterman DC, Peralta L, Rudy BJ, et al. The ACCESS (Adolescents Connected to Care, Evaluation, and Special Services) Project: social marketing to promote HIV testing to adolescents, methods and first year results from a six city campaign. J Adolesc Health. 2001;29S:19-29. [pmid: 11530300].
310 Centers for Disease Control and Prevention. HIV testing among pregnant women — United States and Canada, 1998-2001. Morb Mortal Wkly Rep. 2002;51(45):1013-1016.
311 Fernandez MI, Wilson TE, Ethier KA, et al. Acceptance of HIV testing during prenatal care. Public Health Rep. 2000;115(5):460-468. [pmid: 11236018]. [pmcid: 1308602].
312 Stanley B, Fraser J, Cox NH. Uptake of HIV screening in genitourinary medicine after change to “opt-out” consent. BMJ. 2003;326(7400):1174. [pmid: 12775616]. [pmcid: 156454].
313 Hoffman RE, Spencer NE, Miller LA. Comparison of partner notification at anonymous and confidential HIV test sites in Colorado. J Acquir Immune Defic Syndr Hum Retrovirol. 1995;8(4):406-410. [pmid: 7882107].
314 Landis SE, Schoenbach VJ, Weber DJ, et al. Results of a randomized trial of partner notification in cases of HIV infection in North Carolina. N Engl J Med. 1992;326(2):101-106. [pmid: 1445500].
315 Wykoff RF, Jones JL, Longshore ST, et al. Notification of the sex and needle-sharing partners of individuals with human immunodeficiency virus in rural South Carolina: 30-month experience. Sex Transm Dis. 1991;18(4):217-222. [pmid: 1771474].
316 Toomey KE, Peterman TA, Dicker LW, et al. Human Immunodeficiency Virus Partner Notification: Cost and Effectiveness Data From an Attempted Randomized Controlled Trial. Sex Transm Dis. 1998;25(6):310-316. [pmid: 9662766].
317 Rutherford GW, Woo JM, Neal DP, et al. Partner notification and the control of human immunodeficiency virus infection. Two years of experience in San Francisco. Sex Transm Dis. 1991;18(2):107-110. [pmid: 1862458].
318 Centers for Disease Control and Prevention. Anonymous or confidential HIV counseling and voluntary testing in federally funded testing sites - United States, 1995-1997. Morb Mortal Wkly Rep. 1999;48(24):509-513.
319 Meehan TM, Hansen H, Klein WC. The impact of parental consent on the HIV testing of minors. Am J Public Health. 1997;87(8):1338-1341. [pmid: 9279271]. [pmcid: 1381096].
320 Centers for Disease Control and Prevention. HIV testing among populations at risk for HIV infection - nine states, November 1995–December 1996. Morb Mortal Wkly Rep. 1998;47:1086-1091.
321 Hirano D, Gellert GA, Fleming K, et al. Anonymous HIV testing: the impact of availability on demand in Arizona. Am J Public Health. 1994;84(12):2008-2010. [pmid: 7998649]. [pmcid: 1615379].
322 Fehrs LJ, Fleming D, Foster LR, et al. Trial of anonymous versus confidential human immunodeficiency virus testing. Lancet. 1988;2(8607):379-382. [pmid: 2899784].
323 Hertz-Picciotto I, Lee LW, Hoyo C. HIV test-seeking before and after the restriction of anonymous testing in North Carolina. Am J Public Health. 1996;86(10):1446-1450. [pmid: 8876517]. [pmcid: 1380659].
324 Bindman AB, Osmond D, Hecht FM, et al. Multistate evaluation of anonymous HIV testing and access to medical care. JAMA. 1998;280(16):1416-1420. [pmid: 9801001].
325 Hoxworth T, Hoffman R, Cohn D, et al. Anonymous HIV testing: does it attract clients who would not seek confidential testing?. AIDS Public Policy J. 1994;9(4):182-189. [pmid: 11654295].
326 Nakashima AK, Horsley R, Frey RL, et al. Effect of HIV reporting by name on use of HIV testing in publicly funded counseling and testing programs. JAMA. 1998;280(16):1421-1426. [pmid: 9801002].
327 Castrucci BC, Williams DE, Foust E. The elimination of anonymous HIV testing: a case study in North Carolina. J Public Health Manag Pract. 2002;8(6):30-37. [pmid: 12463048].
328 Hecht FM, Chesney MA, Lehman JS, et al. Does HIV reporting by name deter testing? MESH Study Group. AIDS. 2000;14(12):1801-1808. [pmid: 10985318].
329 Berger SG, Hong BA, Eldridge S, et al. Return rates and partner notification in HIV-positive men seeking anonymous versus confidential antibody testing. AIDS Patient Care STDS. 1999;13(6):363-368. [pmid: 10842857].
330 Osmond DH, Bindman AB, Vranizan K, et al. Name-based surveillance and public health interventions for persons with HIV infection. Ann Intern Med. 1999;131(10):775-779. [pmid: 10577302].
331 Hutchinson AB, Corbie-Smith G, Thomas SB, et al. Understanding the patient's perspective on rapid and routine HIV testing in an inner-city urgent care center. AIDS Educ Prev. 2004;16(2):101-114. [pmid: 15134119].
332 Woods WJ, Sabatino J, Bauer PL, et al. HIV testing in gay sex clubs. Int J STD AIDS. 2000;11(3):173-175. [pmid: 10726941].
333 Spielberg F, Critchlow C, Vittinghoff E, et al. Slow diffusion of home HIV-specimen collection: provider concerns at odds with client preferences. Sex Transm Dis. 2001;28(1):51-57. [pmid: 11196048].
334 Greensides DR, Berkelman R, Lansky A, et al. Alternative HIV testing methods among populations at high risk for HIV infection. Public Health Rep. 2003;118(6):531-539. [pmid: 14563910]. [pmcid: 1497600].
335 Peralta L, Constantine N, Griffin Deeds B, et al. Evaluation of youth preferences for rapid and innovative human immunodeficiency virus antibody tests. Arch Pediatr Adolesc Med. 2001;155(7):838-843. [pmid: 11434854].
336 Spielberg F, Branson BM, Goldbaum GM, et al. Overcoming barriers to HIV testing: preferences for new strategies among clients of a needle exchange, a sexually transmitted disease clinic, and sex venues for men who have sex with men. J Acquir Immune Defic Syndr. 2003;32(3):318-327. [pmid: 12626893].
337 Colfax GN, Lehman JS, Bindman AB, et al. What happened to home HIV test collection kits? Intent to use kits, actual use, and barriers to use among persons at risk for HIV infection. AIDS Care. 2002;14(5):675-682. [pmid: 12419117].
338 Phillips KA, Flatt SJ, Morrison KR, et al. Potential use of home HIV testing. N Engl J Med. 1995;332:1308-1311. [pmid: 7708086].
339 Phillips KA, Morin S, Coates T, et al. Home sample collection for HIV testing. JAMA. 2000;283:198-199. [pmid: 10634330].
340 Pugatch DL, Levesque BG, Lally MA, et al. HIV testing among young adults and older adolescents in the setting of acute substance abuse treatment. J Acquir Immune Defic Syndr. 2001;27(2):135-142. [pmid: 11404535].
341 Skolnik HS, Phillips KA, Binson D, et al. Deciding where and how to be tested for HIV: what matters most?. J Acquir Immune Defic Syndr. 2001;27(3):292-300. [pmid: 11464151].
342 Kelen GD, Shahan JB, Quinn TC. Emergency department-based HIV screening and counseling: experience with rapid and standard serologic testing. Ann Emerg Med. 1999;33(2):147-155. [pmid: 9922409].
343 Kendrick SR, Kroc KA, Couture E, et al. Comparison of point-of-care rapid HIV testing in three clinical venues. AIDS. 2004;18(16):2208-2210. [pmid: 15577658].
344 Branson BM. Home sample collection tests for HIV infection. JAMA. 1998;280(19):1699-1701. [pmid: 9832003].
345 McQuitty M, McFarland W, Kellogg TA, et al. Home collection versus publicly funded HIV testing in San Francisco: who tests where?. J Acquir Immune Defic Syndr. 1999;21(5):417-422. [pmid: 10458624].
346 Sy FS, Rhodes SD, Choi ST, et al. The acceptability of oral fluid testing for HIV antibodies. A pilot study in gay bars in a predominantly rural state. Sex Transm Dis. 1998;25(4):211-215. [pmid: 9564724].
347 Kassler WJ, Dillon BA, Haley C, et al. On-site, rapid HIV testing with same-day results and counseling. AIDS. 1997;11(8):1045-1051. [pmid: 9223740].
348 Samet JH, Freedberg KA, Savetsky JB, et al. Understanding delay to medical care for HIV infection: the long-term non-presenter. AIDS. 2001;15(1):77-85. [pmid: 11192871].
349 Katz MH, Bindman AB, Keane D, et al. CD4 lymphocyte count as an indicator of delay in seeking human immunodeficiency virus-related treatment. Arch Intern Med. 1992;152(7):1501-1504. [pmid: 1352676].
350 Luby S, Jones J, Horan J. Using CD4 counts to evaluate the stages and epidemiology of HIV infection in South Carolina public clinic patients. Am J Public Health. 1994;84(3):377-381. [pmid: 7907458]. [pmcid: 1614853].
351 Hutchinson CM, Wilson C, Reichart CA, et al. CD4 lymphocyte concentrations in patients with newly identified HIV infection attending STD clinics. JAMA. 1991;266(2):253-256. [pmid: 1676076].
352 Dybul M, Bolan R, Condoluci D, et al. Evaluation of initial CD4+ T cell counts in individuals with newly diagnosed human immunodeficiency virus infection, by sex and race, in urban settings. J Infect Dis. 2002;185(12):1818-1821. [pmid: 12085332].
353 Easterbrook PJ, Ly MY, Goetghebeur E, et al. Ten-year trends in CD4 cell counts at HIV and AIDS diagnosis in a London HIV clinic. AIDS. 2000;14:561-571. [pmid: 10780719].
354 Sackoff J, Shin SS. Trends in immunologic and clinical status of newly diagnosed HIV-positive patients initiating care in the HAART era. J Acquir Immune Defic Syndr. 2001;28(3):270-272. [pmid: 11694835].
355 Samet JH, Freedberg KA, Stein MD, et al. Trillion virion delay: time from testing positive for HIV to presentation for primary care. Arch Intern Med. 1998;158(7):734-740. [pmid: 9554679].
356 Samet JH, Retondo MJ, Freedberg KA, et al. Factors associated with initiation of primary medical care for HIV-infected persons. Am J Med. 1994;97:347-353. [pmid: 7942936].
357 Dworkin MS, Hanson DL, Kaplan JE, et al. Risk for preventable opportunistic infections in persons with AIDS after antiretroviral therapy increases CD4+ T lymphocyte counts above prophylaxis thresholds. J Infect Dis. 2000;182(2):611-615. [pmid: 10915098].
358 Kirk O, Lundgren JD, Pedersen C, et al. Can chemoprophylaxis against opportunistic infections be discontinued after an increase in CD4 cells induced by highly active antiretroviral therapy?. AIDS. 1999;13:1647-1651. [pmid: 10509565].
359 Trikalinos TA, Ioannidis JP. Discontinuation of Pneumocystis carinii prophylaxis in patients infected with human immunodeficiency virus: a meta-analysis and decision analysis. Clin Infect Dis. 2001;33(11):1901-1909. [pmid: 11692302].
360 Koletar SL, Heald AE, Finkelstein D, et al. A prospective study of discontinuing primary and secondary Pneumocystis carinii pneumonia prophylaxis after CD4 cell count increase to > 200 × 106 /l. AIDS. 2001;15(12):1509-1515. [pmid: 11504983].
361 Weverling GJ, Mocroft A, Ledergerber B, et al. Discontinuation of Pneumocystis carinii pneumonia prophylaxis after start of highly active antiretroviral therapy in HIV-1 infection. EuroSIDA Study Group. Lancet. 1999;353(9161):1293-1298. [pmid: 10218526].
362 Furrer H, Egger M, Opravil M, et al. Discontinuation of primary prophylaxis against Pneumocystis carinii pneumonia in HIV-1-infected adults treated with combination antiretroviral therapy. Swiss HIV Cohort Study. N Engl J Med. 1999;340(17):1301-1306. [pmid: 10219064].
363 Mussini C, Pezzotti P, Govoni A, et al. Discontinuation of primary prophylaxis for Pneumocystis carinii pneumonia and toxoplasmic encephalitis in human immunodeficiency virus type I-infected patients: the changes in opportunistic prophylaxis study. J Infect Dis. 2000;181(5):1635-1642. [pmid: 10823763].
364 Schneider MM, Borleffs JC, Stolk RP, et al. Discontinuation of prophylaxis for Pneumocystis carinii pneumonia in HIV-1-infected patients treated with highly active antiretroviral therapy. Lancet. 1999;353(9148):201-203. [pmid: 9923876].
365 Yangco BC, Von Bargen JC, Moorman AC, et al. Discontinuation of chemoprophylaxis against Pneumocystis carinii pneumonia in patients with HIV infection. Outpatient Study (HOPS) Investigators. Ann Intern Med. 2000;132(3):201-205. [pmid: 10651600].
366 de Quiros LB. Randomized trial of the discontinutation of primary and secondary prophylaxis against Pneumocystis carinii pneumonia after highly active antiretroviral therapy in patients with HIV infection. N Engl J Med. 2001;344(3):159-167. [pmid: 11172138].
367 Furrer H, Opravil M, Rossi M, et al. Discontinuation of primary prophylaxis in HIV-infected patients at high risk of Pneumocystis carinii pneumonia: prospective multicentre study. AIDS. 2001;15(4):501-507. [pmid: 11242147].
368 Furrer H, Opravil M, Bernasconi E, et al. Stopping primary prophylaxis in HIV-1-infected patients at high risk of toxoplasma encephalitis. Swiss HIV Cohort Study. Lancet. 2000;355(9222):2217-2218. [pmid: 10881897].
369 Currier JS, Williams PL, Koletar SL, et al. Discontinuation of Mycobacterium avium complex prophylaxis in patients with antiretroviral therapy-induced increases in CD4+ cell count. A randomized, double-blind, placebo-controlled trial. AIDS Clinical Trials Group 362 Study Team. Ann Intern Med. 2000;133(7):493-503. [pmid: 11015162].
370 Furrer H, Telenti A, Rossi M, et al. Discontinuing or withholding primary prophylaxis against Mycobacterium avium in patients on successful antiretroviral combination therapy. The Swiss HIV Cohort Study. AIDS. 2000;14(10):1409-1412. [pmid: 10930156].
371 El-Sadr WM, Burman WJ, Grant LB, et al. Discontinuation of prophylaxis for Mycobacterium avium complex disease in HIV-infected patients who have a response to antiretroviral therapy. Terry Beirn Community Programs for Clinical Research on AIDS. N Engl J Med. 2000;342(15):1085-1092. [pmid: 10766581].
372 Strauss SM, Rindskopf DM, Deren S, et al. Concurrence of drug users' self-report of current HIV status and serotest results. J Acquir Immune Defic Syndr. 2001;27(3):301-307. [pmid: 11464152].
373 Centers for Disease Control and Prevention. HIV counseling and testing in publicly funded sites Annual Report 1997 and 1998. Available at: http://www.cdc.gov/hiv/pubs/cts98.pdf. Accessed March 3, 2005.
374 Sullivan PS, Lansky A, Drake A. Failure to return for HIV test results among persons at high risk for HIV infection. J Acquir Immune Defic Syndr. 2004;35(5):511-518. [pmid: 15021316].
375 Molitor F, Bell RA, Truax SR, et al. Predictors of failure to return for HIV test result and counseling by test site type. AIDS Educ Prev. 1999;11(1):1-13. [pmid: 10070585].
376 Hightow LB, Miller WC, Leone PA, et al. Failure to return for HIV posttest counseling in an STD clinic population. AIDS Educ Prev. 2003;15(3):282-290. [pmid: 12866839].
377 Fry LJ, Fernandez RA. HIV prevention: factors that predict compliance with testing and counseling procedures. Journal of the American Osteopathic Association. 1994;94(10):825-830. [pmid: 7814276].
378 Kassler WJ. Advances in HIV testing technology and their potential impact on prevention. AIDS Educ Prev. 1997;9(3 Suppl):27-40. [pmid: 9241396].
379 Keenan PA, Keenan JM. Rapid HIV testing in urban outreach: a strategy for improving posttest counseling rates. AIDS Educ Prev. 2001;13(6):541-550. [pmid: 11791785].
380 Turner BJ, Cunningham WE, Duan N, et al. Delayed medical care after diagnosis in a US national probability sample of persons infected with human immunodeficiency virus. Arch Intern Med. 2000;160(17):2614-2622. [pmid: 10999975].
381 Centers for Disease Control and Prevention. Supplement to HIV/AIDS surveillance (SHAS): demographics and behavioral data from a supplemental HIV/AIDS behavioral surveillance project 1997-2000. Atlanta: US Department of Health and Human Services, Centers for Disease Control and Prevention; 2004.
382 Eichler MR, Ray MS, del Rio C. The effectiveness of HIV post-test counselling in determining healthcare-seeking behavior. AIDS. 2002;16(6):943-945. [pmid: 11919504].
383 Stall R, Pollack L, Mills TC, et al. Use of antiretroviral therapies among HIV-infected men who have sex with men: a household-based sample of 4 major American cities. Am J Public Health. 2001;91(5):767-773. [pmid: 11344885]. [pmcid: 1446670].
384 Cunningham WE, Markson LE, Andersen RM, et al. Prevalence and predictors of highly active antiretroviral therapy use in patients with HIV infection in the United States. J Acquir Immune Defic Syndr. 2000;25(2):115-123. [pmid: 11103041].
385 Kaplan JE, Parham DL, Soto-Torres L, et al. Adherence to guidelines for antiretroviral therapy and for preventing opportunistic infections in HIV-infected adults and adolescents in Ryan White-funded facilities in the United States. J Acquir Immune Defic Syndr. 1999;21(3):228-235. [pmid: 10421247].
386 McNaghten AD, Hanson DL, Dworkin MS, et al. Differences in prescription of antiretroviral therapy in a large cohort of HIV-infected patients. J Acquir Immune Defic Syndr. 2003;32(5):499-505. [pmid: 12679701].
387 Comulada WS, Swendeman DT, Rotheram-Borus MJ, et al. Use of HAART among young people living with HIV. Am J Health Behav. 2003;27(4):389-400. [pmid: 12882433].
388 Jacobson LP, Gore ME, Strathdee SA, et al. Therapy naivete in the era of potent antiretroviral therapy. J Clin Epidemiol. 2001;54(2):149-156. [pmid: 11166530].
389 Schwarz DF, Henry-Reid L, Houser J, et al. The association of perceived health, clinical status, and initiation of HAART (highly active antiretroviral therapy) in adolescents. J Adolesc Health. 2001;29(3, Supplement 1):115-122. [pmid: 11530312].
390 Celentano DD, Vlahov D, Cohn S, et al. Self-reported Antiretroviral Therapy in Injection Drug Users. JAMA. 1998;280(6):544-546. [pmid: 9707145].
391 Thomas K, Rubino L, O'Connor A, et al. How Common Is Choosing to Discontinue Treatment for HIV?. Am J Public Health. 2002;92(3):364. [pmid: 11867310]. [pmcid: 1447079].
392 Lucas GM, Cheever LW, Chaisson RE, et al. Detrimental Effects of Continued Illicit Drug Use on the Treatment of HIV-1 Infection. J Acquir Immune Defic Syndr. 2001;27(3):251-259. [pmid: 11464144].
393 Bassetti S, Battegay M, Furrer H, et al. Why is highly active antiretroviral therapy (HAART) not prescribed or discontinued? Swiss HIV Cohort Study. J Acquir Immune Defic Syndr. 1999;21(2):114-119. [pmid: 10360802].
394 Strathdee SA, Palepu A, Cornelisse PGA, et al. Barriers to use of free antiretroviral therapy in injection drug users. JAMA. 1998;280:547-549. [pmid: 9707146].
395 Cook JA, Cohen MH, Burke J, et al. Effects of depressive symptoms and mental health quality of life on use of highly active antiretroviral therapy among HIV-seropositive women. J Acquir Immune Defic Syndr. 2002;30(4):401-409. [pmid: 12138346].
396 Palacio H, Kahn JG, Richards TA, et al. Effect of Race and/or Ethnicity in Use of Antiretrovirals and Prophylaxis for Opportunistic Infection: A Review of the Literature. Public Health Rep. 2002;117(3):233-251. [pmid: 12432135]. [pmcid: 1497431].
397 Kahn JG, Zhang X, Cross LT, et al. Access to and Use of HIV Antiretroviral Therapy: Variation by Race/Ethnicity in Two Public Insurance Programs in the U.S. Public Health Rep. 2002;117(3):252-262. [pmid: 12432136]. [pmcid: 1497435].
398 Sackoff J, McFarland J, Su S, et al. Prophylaxis for opportunistic infections among HIV-infected patients receiving medical care. J Acquir Immune Defic Syndr Hum Retrovirol. 1998;19(4):387-392. [pmid: 9833748].
399 Morin SF, Koester KA, Steward WT, et al. Missed opportunities: prevention with HIV-infected patients in clinical care settings. J Acquir Immune Defic Syndr. 2004;36(4):960-966. [pmid: 15220703].
400 Centers for Disease Control and Prevention. Diagnosis and reporting of HIV and AIDS in states with HIV/AIDS surveillance—United States, 1994-2000. Morb Mortal Wkly Rep. 2002;51:595-598.
401 Centers for Disease Control and Prevention. Implementation of named HIV reporting—New York City, 2001. Morb Mortal Wkly Rep. 2004;52(5152):1248-1252.
402 Kamimoto L, McKenna M. A population-based assessment of CD4 test restuls in newly diagnosed, HIV-infected persons. Paper presented at: 11th Conference on Retroviruses and Opportunistic Infections, 2004; San Francisco, CA.
403 Centers for Disease Control and Prevention. AIDS cases, deaths, and persons living with AIDS by year, 1985-2002—United States. Available at: http://www.cdc.gov/hiv/stats/hasr1402.htm. Accessed Dec. 2, 2004.
404 Neal JJ, Fleming PL. Frequency and Predictors of Late HIV Diagnosis in the United States, 1994 through 1999. Paper presented at: 9th Conference on Retroviruses and Opportunistic Infections, 2002; Seattle, WA.
405 Schwarcz S, Hsu LC. AIDS in the HAART Era: the Extent and Characteristics of Late HIV Testers. Paper presented at: 11th Conference on Retroviruses and Opportunistic Infections, 2004; San Francisco, CA.
406 Girardi E, Aloisi MS, Arici C, et al. Delayed presentation and late testing for HIV: demographic and behavioral risk factors in a multicenter study in Italy. J Acquir Immune Defic Syndr. 2004;36(4):951-959. [pmid: 15220702].
407 Couturier E, Schwoebel V, Michon C, et al. Determinants of delayed diagnosis of HIV infection in France, 1993-1995. AIDS. 1998;12(7):795-800. [pmid: 9619812].
408 Wortley PM, Chu SY, Diaz T, et al. HIV testing patterns: where, why and when were persons with AIDS tested for HIV?. AIDS. 1995;9:487-492. [pmid: 7639974].
409 Porter K, Wall PG, Evans BG. Factors Associated with Lack of Awareness of HIV Infection Before Diagnosis of AIDS. BMJ. 1993;307(6895):20-23. [pmid: 8343662]. [pmcid: 1678470].
410 Gillieatt SJ, Mallal SA, French MAH, et al. Epidemiology of late presentation of HIV infection in Western Australia. Med J Aust. 1992;157:117-118. [pmid: 1630373].
411 Kaldor JM, French MAH. When do patients present with HIV infection?. Med J Aust. 1993;158:37-38. [pmid: 8417289].
412 Poznansky MC, Coker R, Skinner C, et al. HIV Positive Patients First Presenting with an AIDS Defining Illness: Characteristics and Survival. BMJ. 1995;311(6998):156-158. [pmid: 7613426]. [pmcid: 2550220].
413 Girardi E, Sampaolesi A, Gentile M, et al. Increasing proportion of late diagnosis of HIV infection among patients with AIDS in Italy following introduction of combination antiretroviral therapy. J Acquir Immune Defic Syndr. 2000;25(1):71-76. [pmid: 11064507].
414 Garcia F, de Lazzari E, Plana M, et al. Long-Term CD4+ T-Cell Response to Highly Active Antiretroviral Therapy According to Baseline CD4+ T-Cell Count. J Acquir Immune Defic Syndr. 2004;36(2):702-713. [pmid: 15167289].
415 Wood E, Hogg RS, Yip B, et al. Is there a baseline CD4 cell count that precludes a survival response to modern antiretroviral therapy?. AIDS. 2003;17(5):711-720. [pmid: 12646794].
416 Re MC, Ramazzotti E, Manfredi R, et al. Viral load trend in HIV-1 seropositive patients with different CD4 cell counts before starting HAART. J Clin Virol. 2000;17(1):5-11. [pmid: 10814933].
417 Phillips AN, Staszewski S, Weber R, et al. HIV viral load response to antiretroviral therapy according to the baseline CD4 cell count and viral load. JAMA. 2001;286(20):2560-2567. [pmid: 11722270].
418 Kazempour K, Kammerman LA, Farr SS. Survival effects of ZDV, ddI, and ddC in patients with CD4 < or = 50 cells/mm3. J Acquir Immune Defic Syndr Hum Retrovirol. 1995;10(Suppl 2):S97-106. [pmid: 7552521].
419 Haas DW, Morgan ME, Harris VL. Increased viral load and suicidal ideation in an HIV-infected patient. Ann Intern Med. 1997;126(1):86-87. [pmid: 8992930].
420 Carr A. Antiretroviral therapy for previously untreated HIV-1-infected adults: 2NN, or just one?. Lancet. 2004;363:1248-1250. [pmid: 15094265].
421 Jordan R, Gold L, Cummins C, et al. Systematic review and meta-analysis of evidence for increasing numbers of drugs in antiretroviral combination therapy. BMJ. 2002;324(7340):1-10. [pmid: 11777781]. [pmcid: 1121932].
422 D'Aquila RT, Johnson VA, Welles SL, et al. Zidovudine resistance and HIV-1 disease progression during antiretroviral therapy. AIDS Clinical Trials Group Protocol 116B/117 Team and the Virology Committee Resistance Working Group. Ann Intern Med. 1995;122(6):401-408. [pmid: 7856987].
423 Gulick RM, Meibohm A, Havlir D, et al. Six-year follow-up of HIV-1-infected adults in a clinical trial of antiretroviral therapy with indinavir, zidovudine, and lamivudine. AIDS. 2003;17(16):2345-2349. [pmid: 14571186].
424 Gulick RM, Mellors JW, Havlir D, et al. 3-year suppression of HIV viremia with indinavir, zidovudine, and lamivudine. Ann Intern Med. 2000;133(1):35-39. [pmid: 10877738].
425 Servais J, Schmit JC, Arendt V, et al. Three-year effectiveness of highly active antiretroviral treatment in the Luxembourg HIV cohort. HIV Clinical Trials. 2000;1(2):17-24. [pmid: 11590494].
426 Phillips AN, Miller V, Sabin C, et al. Durability of HIV-1 viral suppression over 3.3 years with multi-drug antiretroviral therapy in previously drug-naive individuals. AIDS. 2001;15(18):2379-2384. [pmid: 11740188].
427 Siciliano JD, Kajdas J, Finzi D, et al. Long-term follow-up studies confirm the stability of the latent reservoir for HIV-1 in resting CD4+ T cells. Nature Medicine. 2003;9(6):727-728.
428 Finzi D, Hermankova M, Pierson T, et al. Identification of a reservoir for HIV-1 in patients on highly active antiretroviral therapy. Science. 1997;278(5341):1295-1300. [pmid: 9360927].
429 Chun TW, Stuyver L, Mizell SB, et al. Presence of an inducible HIV-1 latent reservoir during highly active antiretroviral therapy. Proc Natl Acad Sci USA. 1997;94(24):13193-13197. [pmid: 9371822]. [pmcid: 24285].
430 Yazdanpanah Y, Sissoko D, Egger M, et al. Clinical efficacy of antiretroviral combination therapy based on protease inhibitors or non-nucleoside analogue reverse transcriptase inhibitors: indirect comparison of controlled trials. BMJ. 2004;328:249-255. [pmid: 14742351]. [pmcid: 324449].
431 van Leth F, Phanuphak P, Ruxrungtham K, et al. Comparison of first-line antiretroviral therapy with regimens including nevirapine, efavirenz, or both drugs, plus stavudine and lamivudine: a randomised open-label trial, the 2NN Study. Lancet. 2004;363:1253-1263. [pmid: 15094269].
432 Kirk O, Katzenstein TL, Gerstoft J, et al. Combination therapy containing ritonavir plus saquinavir has superior short-term antiretroviral efficacy: a randomized trial. AIDS. 1999;13(1):F9-16. [pmid: 10449275].
433 Gerstoft J, Kirk O, Obel N, et al. Low efficacy and high frequency of adverse events in a randomized trial of the triple nucleoside regimen abacavir, stavudine and didanosine. AIDS. 2003;17(14):2045-2052. [pmid: 14502007].
434 Shafer RW, Smeaton LM, Robbins GK, et al. Comparison of four-drug regimens and pairs of sequential three-drug regimens as initial therapy for HIV-1 infection. N Engl J Med. 2003;349:2304-2315. [pmid: 14668456].
435 Gulick RM, Ribaudo HJ, Shikuma CM, et al. Triple-Nucleoside Regimens versus Efavirenz-Containing Regimens for the Initial Treatment of HIV-1 Infection. N Engl J Med. 2004;350(18):1850-1861. [pmid: 15115831].
436 Chene G, Sterne JA, May M, et al. Prognostic importance of initial response in HIV-1 infected patients starting potent antiretroviral therapy: analysis of prospective studies. Lancet. 2003;362(9385):679-686. [pmid: 12957089].
437 HIV Trialists' Collaborative Group. Zidovudine, didanosine, and zalcitabine in the treatment of HIV infection: meta-analyses of the randomised evidence. Lancet. 1999;353(9169):2014-2025. [pmid: 10376616].
438 Darbyshire J, Foulkes M, Peto R, et al. Zidovudine (AZT) versus AZT plus didanosine (ddI) versus AZT plus zalcitabine (ddC) in HIV infected adults (Cochrane Review). The Cochrane Library. Chichester, UK: John Wiley & Sons, Ltd.; 2003.
439 Staszewski S, Hill AM, Bartlett J, et al. Reductions in HIV-1 disease progression for zidovudine/lamivudine relative to control treatments: a meta-analysis of controlled trials. AIDS. 1997;11(4):477-483. [pmid: 9084795].
440 Palella FJ, Delaney KM, Moorman AC, et al. Declining morbidity and mortality among patients with advanced human immunodeficiency virus infection. N Engl J Med. 1998;338(13):853-860. [pmid: 9516219].
441 Moore RD, Chaisson RE. Natural history of HIV infection in the era of combination antiretroviral therapy. AIDS. 1999;13(14):1933-1942. [pmid: 10513653].
442 Egger M, Hirschel B, Francioli P, et al. Impact of new antiretroviral combination therapies in HIV infected patients in Switzerland: prospective multicentre study. BMJ. 1997;315(7117):1194-1199. [pmid: 9393221]. [pmcid: 2127760].
443 Mocroft A, Vella S, Benfield TL, et al. Changing patterns of mortality across Europe in patients infected with HIV-1. EuroSIDA Study Group. Lancet. 1998;352(9142):1725-1730. [pmid: 9848347].
444 Pezzotti P, Napoli PA, Acciai S, et al. Increasing survival times after AIDS in Italy: the role of new combination antiretroviral therapies. AIDS. 1999;13(2):249-255. [pmid: 10202831].
445 Verbraak FD, Boom R, Wertheim-van Dillen PM, et al. Influence of highly active antiretroviral therapy on the development of CMV disease in HIV positive patients at high risk for CMV disease. Br J Opthalmol. 1999;83(10):1186-1189.
446 Casado JL, Arrizabalaga J, Montes M, et al. Incidence and risk factors for developing cytomegalovirus retinitis in HIV-infected patients receiving protease inhibitor therapy. Spanish CMV-AIDS Study Group. AIDS. 1999;13(12):1497-1502. [pmid: 10465073].
447 Ledergerber B, Egger M, Erard V, et al. AIDS-related opportunistic illnesses occurring after initiation of potent antiretroviral therapy: the Swiss HIV Cohort Study. JAMA. 1999;282(23):2220-2226. [pmid: 10605973].
448 Vittinghoff E, Scheer S, O'Malley P, et al. Combination antiretroviral therapy and recent declines in AIDS incidence and mortality. J Infect Dis. 1999;179(3):717-720. [pmid: 9952385].
449 Detels R, Tarwater P, Phair JP, et al. Effectiveness of potent antiretroviral therapies on the incidence of opportunistic infections before and after AIDS diagnosis. AIDS. 2001;15(3):347-355. [pmid: 11273215].
450 Lee LM, Karon JM, Selik R, et al. Survival after AIDS diagnosis in adolescents and adults during the treatment era, United States, 1984-1997. JAMA. 2001;285(10):1308-1315. [pmid: 11255385].
451 Tarwater PM, Mellors J, Gore ME, et al. Methods to assess population effectiveness of therapies in human immunodeficiency virus incident and prevalent cohorts. Am J Epidemiol. 2001;154(7):675-681. [pmid: 11581102].
452 Louie JK, Hsu LC, Osmond DH, et al. Trends in causes of death among persons with acquired immunodeficiency syndrome in the era of highly active antiretroviral therapy, San Francisco, 1994-1998. J Infect Dis. 2002;186(7):1023-1027. [pmid: 12232845].
453 Centers for Disease Control and Prevention. Update: AIDS—United States, 2000. Morb Mortal Wkly Rep. 2002;51(27):592-595.
454 Sendi PP, Bucher HC, Craig BA, et al. Estimating AIDS-free survival in a severely immunosuppressed asymptomatic HIV-infected population in the era of antiretroviral triple combination therapy. Swiss HIV Cohort Study. J Acquir Immune Defic Syndr Hum Retrovirol. 1999;20(4):376-381. [pmid: 10096582].
455 Dorrucci M, Balducci M, Pezzotti P, et al. Temporal changes in the rate of progression to death among Italians with known date of HIV seroconversion: estimates of the population effect of treatment. Italian HIV Seroconversion Study (ISS). J Acquir Immune Defic Syndr. 1999;22(1):65-70. [pmid: 10534148].
456 van Sighem AI, van de Wiel MA, Ghani AC, et al. Mortality and progression to AIDS after starting highly active antiretroviral therapy. AIDS. 2003;17:2227-2236. [pmid: 14523280].
457 Doan S, Cochereau I, Guvenisik N, et al. Cytomegalovirus retinitis in HIV-infected patients with and without highly active antiretroviral therapy. American Journal of Ophthalmology. 1999;128(2):250-251. [pmid: 10458193].
458 Kirk O, Gatell JM, Mocroft A, et al. Infections with Mycobacterium tuberculosis and Mycobacterium avium among HIV-infected patients after the introduction of highly active antiretroviral therapy. EuroSIDA Study Group JD. Am J Respir Crit Care Med. 2000;162(3 Pt 1):865-872. [pmid: 10988097].
459 Cascade Collaboration. Survival after introduction of HAART in people with known duration of HIV-1 infection. Lancet. 2000;355:1158-1159. [pmid: 10791383].
460 Cascade Collaboration. Changes over calendar time in the risk of specific first AIDS-defining events following HIV seroconversion, adjusting for competing risks. Int J Epidemiol. 2002;31:951-958. [pmid: 12435766].
461 Schnazer DL. Trends in HIV/AIDS mortality in Canada, 1987-1998. Can J Public Health. 2003;94(2):135-139. [pmid: 12675171].
462 Hogg RS, Heath KV, Yip B, et al. Improved survival among HIV-infected individuals following initation of antiretroviral therapy. JAMA. 1998;279:450-454. [pmid: 9466638].
463 Correll PK, Law MG, McDonald AM, et al. HIV disease progression in Australia in the time of combination antiretroviral therapies. Med J Aust. 1998;169(9):469-472. [pmid: 9847898].
464 Dore GJ, Li Y, McDonald A, et al. Impact of highly active antiretroviral therapy on individual AIDS-defining illness incidence and survival in Australia. J Acquir Immune Defic Syndr. 2002;29:388-395. [pmid: 11917244].
465 Mocroft A, Ledergerber B, Katlama C, et al. Decline in the AIDS and death rates in the EuroSIDA study: an observational study. Lancet. 2003;362:22-29. [pmid: 12853195].
466 Carr A, Chuah J, Hudson J, et al. A randomised, open-label comparison of three highly active antiretroviral therapy regimens including two nucleoside analogues and indinavir for previously untreated HIV-1 infection: the OzCombo1 study. AIDS. 2000;14(9):1171-1180. [pmid: 10894281].
467 Cohen Stuart JW, Schuurman R, Burger DM, et al. Randomized trial comparing saquinavir soft gelatin capsules versus indinavir as part of triple therapy (CHEESE study). AIDS. 1999;13(7):F53-58. [pmid: 10357371].
468 Eron JJ, Feinberg J, Kessler HA, et al. Once-daily versus twice-daily lopinavir/ritonavir in antiretroviral-naive HIV-positive patients: a 48-week randomized clinical trial. J Infect Dis. 2004;189(2):265-272. [pmid: 14722892].
469 Eron JJ Jr, Murphy RL, Peterson D, et al. A comparison of stavudine, didanosine and indinavir with zidovudine, lamivudine and indinavir for the initial treatment of HIV-1 infected individuals: selection of thymidine analog regimen therapy (START II). AIDS. 2000;14(11):1601-1610. [pmid: 10983647].
470 Fischl MA, Ribaudo HJ, Collier AC, et al. A randomized trial of 2 different 4-drug antiretroviral regimens versus a 3-drug regimen, in advanced human immunodeficiency virus disease. J Infect Dis. 2003;188(5):625-634. [pmid: 12934177].
471 French M, Amin J, Roth N, et al. Randomized, open-label, comparative trial to evaluate the efficacy and safety of three antiretroviral drug combinations including two nucleoside analogues and nevirapine for previously untreated HIV-1 Infection: the OzCombo 2 study. HIV Clinical Trials. 2002;3(3):177-185. [pmid: 12032876].
472 Gallant JE, Staszewski S, Pozniak AL, et al. Efficacy and safety of tenofovir DF vs. stavudine in combination therapy in antiretroviral-naive patients: a 3-year randomized trial. JAMA. 2004;292(2):191-201. [pmid: 15249568].
473 Garcia F, Knobel H, Sambeat MA, et al. Comparison of twice-daily stavudine plus once- or twice-daily didanosine and nevirapine in early stages of HIV infection: the scan study. AIDS. 2000;14(16):2485-2494. [pmid: 11101059].
474 Gathe J Jr, Badaro R, Grimwood A, et al. Antiviral activity of enteric-coated didanosine, stavudine, and nelfinavir versus zidovudine plus lamivudine and nelfinavir. J Acquir Immune Defic Syndr. 2002;31(4):399-403. [pmid: 12447010].
475 Gathe JC Jr, Ive P, Wood R, et al. SOLO: 48-week efficacy and safety comparison of once-daily fosamprenavir/ritonavir versus twice-daily nelfinavir in naive HIV-1-infected patients. AIDS. 2004;18:1529-1537. [pmid: 15238771].
476 Launay O, Gerard L, Morand-Joubert L, et al. Nevirapine or lamivudine plus stavudine and indinavir: examples of 2-class versus 3-class regimens for the treatment of human immunodeficiency virus type 1. Clin Infect Dis. 2002;35(9):1096-1105. [pmid: 12384844].
477 Maggiolo F, Ripamonti D, Gregis G, et al. Once-a-day therapy for HIV infection: a controlled, randomized study in antiretroviral-naive HIV-1-infected patients. Antivir Ther. 2003;8(4):339-346. [pmid: 14518703].
478 Martinez-Picado J, Negredo E, Ruiz L, et al. Alternation of antiretroviral drug regimens for HIV infection. A randomized, controlled trial. Ann Intern Med. 2003;139(2):81-89. [pmid: 12859157].
479 Matheron S, Descamps D, Boue F, et al. Triple nucleoside combination zidovudine/lamivudine/abacavir versus zidovudine/lamivudine/nelfinavir as first-line therapy in HIV-1-infected adults: a randomized trial. Antivir Ther. 2003;8(2):163-171. [pmid: 12741629].
480 Murphy RL, Brun S, Hicks C, et al. ABT-378/ritonavir plus stavudine and lamivudine for the treatment of antiretroviral-naive adults with HIV-1 infection: 48-week results. AIDS. 2001;15(1):F1-9. [pmid: 11192849].
481 Murphy RL, Sanne I, Cahn P, et al. Dose-ranging, randomized, clinical trial of atazanavir with lamivudine and stavudine in antiretroviral-naive subjects: 48-week results. AIDS. 2003;17(18):2603-2614. [pmid: 14685054].
482 Nunez M, Soriano V, Martin-Carbonero L, et al. SENC (Spanish efavirenz vs. nevirapine comparison) trial: a randomized, open-label study in HIV-infected naive individuals. HIV Clinical Trials. 2002;3(3):186-194. [pmid: 12032877].
483 Podzamczer D, Ferrer E, Consiglio E, et al. A randomized clinical trial comparing nelfinavir or nevirapine associated to zidovudine/lamivudine in HIV-infected naive patients (the Combine Study). Antivir Ther. 2002;7(2):81-90. [pmid: 12212928].
484 Robbins GK, De Gruttola V, Shafer RW, et al. Comparison of sequential three-drug regimens as initial therapy for HIV-1 infection. N Engl J Med. 2003;349(24):2293-2303. [pmid: 14668455].
485 Rodriguez-French A, Boghossian J, Gray GE, et al. The NEAT study: a 48-week open-label study to compare the antiviral efficacy and safety of GW433908 versus nelfinavir in antiretroviral therapy-naive HIV-1-infected patients. J Acquir Immune Defic Syndr. 2004;35(1):22-32. [pmid: 14707788].
486 Saag MS, Cahn P, Raffi F, et al. Efficacy and safety of emtricitabine vs stavudine in combination therapy in antiretroviral-naive patients: a randomized trial. JAMA. 2004;292(2):180-190. [pmid: 15249567].
487 Saag MS, Tebas P, Sension M, et al. Randomized, double-blind comparison of two nelfinavir doses plus nucleosides in HIV-infected patients (Agouron study 511). AIDS. 2001;15(15):1971-1978. [pmid: 11600825].
488 Sanne I, Piliero P, Squires K, et al. Results of a phase 2 clinical trial at 48 weeks (AI424-007): a dose-ranging, safety, and efficacy comparative trial of atazanavir at three doses in combination with didanosine and stavudine in antiretroviral-naive subjects. J Acquir Immune Defic Syndr. 2003;32(1):18-29. [pmid: 12514410].
489 Squires K, Lazzarin A, Gatell JM, et al. Comparison of once-daily atazanavir with efavirenz, each in combination with fixed-dose zidovudine and lamivudine, as initial therapy for patients infected with HIV. J Acquir Immune Defic Syndr. 2004;36(5):1011-1019. [pmid: 15247553].
490 Squires KE, Gulick R, Tebas P, et al. A comparison of stavudine plus lamivudine versus zidovudine plus lamivudine in combination with indinavir in antiretroviral naive individuals with HIV infection: selection of thymidine analog regimen therapy (START I). AIDS. 2000;14(11):1591-1600. [pmid: 10983646].
491 Staszewski S, Morales-Ramirez J, Tashima KT, et al. Efavirenz plus zidovudine and lamivudine, efavirenz plus indinavir, and indinavir plus zidovudine and lamivudine in the treatment of HIV-1 infection in adults. Study 006 Team. N Engl J Med. 1999;341(25):1865-1873. [pmid: 10601505].
492 Staszewski S, Keiser P, Montaner J, et al. Abacavir-lamivudine-zidovudine vs indinavir-lamivudine-zidovudine in antiretroviral-naive HIV-infected adults: A randomized equivalence trial. JAMA. 2001;285(9):1155-1163. [pmid: 11231744].
493 van Leeuwen R, Katlama C, Murphy RL, et al. A randomized trial to study first-line combination therapy with or without a protease inhibitor in HIV-1-infected patients. AIDS. 2003;17(7):987-999. [pmid: 12700448].
494 Walmsley S, Bernstein B, King M, et al. Lopinavirritonavir versus nelfinavir for the initial treatment of HIV infection. N Engl J Med. 2002;346(26):2039-2046. [pmid: 12087139].
495 Revicki DA, Moyle G, Stellbrink HJ, et al. Quality of life outcomes of combination zalcitabine-zidovudine, saquinavir-zidovudine, and saquinavir-zalcitabine-zidovudine therapy for HIV-infected adults with CD4 cell counts between 50 and 350 per cubic millimeter. PISCES (SV14604) Study Group. AIDS. 1999;13(7):851-858. [pmid: 10357386].
496 Bucciardini R, Wu AW, Floridia M, et al. Quality of life outcomes of combination zidovudine- didanosine-nevirapine and zidovudine-didanosine for antiretroviral-naive advanced HIV-infected patients. AIDS. 2000;14(16):2567-2574. [pmid: 11101069].
497 Coplan PM, Cook JR, Carides GW, et al. Impact of indinavir on the quality of life in patients with advanced HIV infection treated with zidouvdine and lamivudine. Clin Infect Dis. 2004;39(3):426-433. [pmid: 15307012].
498 Nieuwkerk PT, Gisolf EH, Colebunders R, et al. Quality of life in asymptomatic- and symptomatic HIV infected patients in a trial of ritonavir/saquinavir therapy. The Prometheus Study Group. AIDS. 2000;14(2):181-187. [pmid: 10708289].
499 Casado A, Badia X, Consiglio E, et al. Health-related quality of life in HIV-infected naive patients treated with nelfinavir or nevirapine associated with ZDV/3TC (the COMBINE-QoL Subsutdy). HIV Clin Trials. 2004;5(3):132-139. [pmid: 15248137].
500 Cohen C, Revicki DA, Nabulsi A, et al. A randomized trial of the effect of ritonavir in maintaining quality of life in advanced HIV disease. Advanced HIV Disease Ritonavir Study Group. AIDS. 1998;12(12):1495-1502. [pmid: 9727571].
501 Nieuwkerk PT, Reijers MH, Weigel HM, et al. Quality of life in maintenance vs prolonged induction therapy for HIV. JAMA. 2000;284(2):178-179. [pmid: 10889587].
502 Nieuwkerk PT, Gisolf EH, Reijers MH, et al. Long-term quality of life outcomes in three antiretroviral treatment strategies for HIV-1 infection. AIDS. 2001;15(15):1985-1991. [pmid: 11600827].
503 Wu AW, Revicki DA, Jacobson D, et al. Evidence for reliability, validity and usefulness of the Medical Outcomes Study HIV Health Survey (MOS-HIV). Qual Life Res. 1997;6(6):481-493. [pmid: 9330549].
504 Wu AW, Rubin HR, Mathews WC, et al. A health status questionnaire using 30 items from the Medical Outcomes Study: preliminary validation in persons with early HIV infection. Med Care. 1991;29:786-798. [pmid: 1875745].
505 Barroso PF, Schechter M, Gupta P, et al. Effect of antiretroviral therapy on HIV shedding in semen. Ann Intern Med. 2000;133:280-284. [pmid: 10929169].
506 Cu-Uvin S, Caliendo AM, Reinert S, et al. Effect of highly active antiretroviral therapy on cervicovaginal HIV-1 RNA. AIDS. 2000;14:415-421. [pmid: 10770544].
507 Porco TC, Martin JN, Page-Shafer KA, et al. Decline in HIV infectivity following the introduction of highly active antiretroviral therapy. AIDS. 2004;18(1):81-88. [pmid: 15090833]. [pmcid: 2442908].
508 Murphy G, Charlett A, Jordan LF, et al. HIV incidence appears constant in men who have sex with men despite widespread use of effective antiretroviral therapy. AIDS. 2004;18(2):265-272. [pmid: 15075544].
509 Katz MH, Schwarcz SK, Kellogg TA, et al. Impact of highly active antiretroviral treatment on HIV seroincidence among men who have sex with men: San Francisco. Am J Public Health. 2002;92(3):388-394. [pmid: 11867317]. [pmcid: 1447086].
510 Scheer S, Chu PL, Klausner KD, et al. Effect of highly active antiretroviral therapy on diagnoses of sexaully transmitted diseases in people with AIDS. Lancet. 2001;357(9254):432-435. [pmid: 11273063].
511 Do AN, Hanson DL, Dworkin MS, et al. Risk factors for and trends in gonorrhea incidence among persons infected with HIV in the United States. AIDS. 2001;15(9):1149-1155. [pmid: 11416717].
512 Wolitski RJ, Valdiserri RO, Denning PH, et al. Are we headed for a resurgence of the HIV epidemic among men who have sex with men?. Am J Public Health. 2001;91:883-888. [pmid: 11392927]. [pmcid: 1446461].
513 Centers for Disease Control and Prevention. Increases in unsafe sex and rectal gonorrhea among men who have sex with men - San Francisco, California, 1994-1997. Morb Mortal Wkly Rep. 1999;48(3):45-48.
514 Centers for Disease Control and Prevention. Resurgent bacterial sexually transmitted disease among men who have sex with men - King County, Washington, 1997-1999. Morb Mortal Wkly Rep. 1999;48(35):773-777.
515 Centers for Disease Control and Prevention. Gonorrhea among men who have sex with men - selected sexually transmitted diseases clinics, 1993-1996. Morb Mortal Wkly Rep. 1997;46(38):889-892.
516 Centers for Disease Control and Prevention. Trends in primary and secondary syphilis and HIV infections in men who have sex with men - San Francisco and Los Angeles, California, 1998-2002. Morb Mortal Wkly Rep. 2004;53(26):575-578.
517 Blair JM, Hanson DL, Jones JL, et al. Trends in pregnancy rates among women with human immunodeficiency virus. Obstet Gynecol. 2004;103(4):663-668. [pmid: 15051556].
518 Crepaz N, Marks G. Towards an understanding of sexual risk behavior in people living with HIV: a review of social, psychological, and medical findings. AIDS. 2002;16:135-149. [pmid: 11807297].
519 Crepaz N, Marks G. Are negative affective states associated with HIV sexual risk behaviors? A meta-analytic review. Health Psychol. 2001;20(4):291-299. [pmid: 11515741].
520 Crepaz N, Hart TA, Marks G. Highly active antiretroviral therapy and sexual risk behavior. JAMA. 2004;292(2):224-236. [pmid: 15249572].
521 Wolf K, Young J, Rickenbach M, et al. Prevalence of unsafe sexual behavior among HIV-infected individuals: the Swiss HIV Cohort Study. J Acquir Immune Defic Syndr. 2003;33(4):494-499. [pmid: 12869838].
522 Stolte IG, Dukers NH, Geskus RB, et al. Homosexual men change to risky sex when perceiving less threat of HIV/AIDS since availability of highly active antiretroviral therapy: a longitudinal study. AIDS. 2004;18(2):303-309. [pmid: 15075549].
523 Stolte IG, de Wit JBF, van Eeden A, et al. Perceived viral load, but not actual HIV-1-RNA load, is associated with sexual risk behaviour among HIV-infected homosexual men. AIDS. 2004;18:1943-1949. [pmid: 15353980].
524 Tun W, Gange SJ, Vlahov D, et al. Increase in sexual risk behavior associated with immunologic response to highly active antiretroviral therapy among HIV-infected injection drug users. Clin Infect Dis. 2004;38:1167-1174. [pmid: 15095224].
525 Musicco M, Lazzarin A, Nicolosi A, et al. Antiretroviral treatment of men infected with human immunodeficiency virus type 1 reduces the incidence of heterosexual transmission. Arch Intern Med. 1994;154(17):1971-1976. [pmid: 8074601].
526 Holtgrave DR. Estimation of annual HIV transmission rates in the United States, 1978-2000. J Acquir Immune Defic Syndr. 2004;35(1):89-92. [pmid: 14707798].
527 Janssen RS, Holtgrave DR, Valdiserri RO, et al. The serostatus approach to fighting the HIV epidemic: prevention strategies for infected individuals. Am J Public Health. 2001;91(7):1019-1024. [pmid: 11441723]. [pmcid: 1446705].
528 Centers for Disease Control and Prevention. Technical guidance on HIV counseling. JAMA. 1993;269(16):2072-2076. [pmid: 8385715].
529 Centers for Disease Control and Prevention, Health Resources Services Administration, National Institutes of Health, et al. Incorporating HIV prevention into the medical care of persons living with HIV. Recommendations of CDC, the Health Resources and Services Administration, the National Institutes of Health, and the HIV Medicine Association of the Infectious Diseases Society of America. Morb Mortal Wkly Rep Recommendations and Reports. 2003;52(RR-12):1-24.
530 Centers for Disease Control and Prevention. HIV testing—United States, 2001. Morb Mortal Wkly Rep. 2003;52(23):540-545.
531 Padian NS, O'Brien TR, Chang Y, et al. Prevention of heterosexual transmission of human immunodeficiency virus through couple counseling. J Acquir Immune Defic Syndr. 1993;6(9):1043-1048. [pmid: 8340895].
532 Allen S, Tice J, Van de Perre P, et al. Effect of serotesting with counselling on condom use and seroconversion among HIV discordant couples in Africa. BMJ. 1992;304(6842):1605-1609. [pmid: 1628088]. [pmcid: 1881972].
533 Otten MW Jr, Zaidi AA, Wroten JE, et al. Changes in sexually transmitted disease rates after HIV testing and posttest counseling, Miami, 1988 to 1989. Am J Public Health. 1993;83(4):529-533. [pmid: 8460729]. [pmcid: 1694465].
534 Chamot E, Coughlin SS, Farley TA, et al. Gonorrhea incidence and HIV testing and counseling among adolescents and young adults seen at a clinic for sexually transmitted diseases. AIDS. 1999;13(8):971-979. [pmid: 10371179].
535 Zenilman JM, Erickson B, Fox R, et al. Effect of HIV posttest counseling on STD incidence. JAMA. 1992;267(6):843-845. [pmid: 1732658].
536 Kamb ML, Fishbein M, Douglas JM Jr, et al. Project RESPECT Study Group. Efficacy of risk-reduction counseling to prevent human immunodeficiency virus and sexually transmitted diseases: a randomized controlled trial. JAMA. 1998;280(13):1161-1167. [pmid: 9777816].
537 Wingood GM, DiClemente RJ, Mikhail I, et al. A randomized controlled trial to reduce HIV transmission risk behaviors and sexually transmitted diseases among women living with HIV. J Acquir Immune Defic Syndr. 2004;37(2 Suppl):S58-S67. [pmid: 15385901].
538 Boyer CB, Barrett DC, Peterman TA, et al. Sexually transmitted disease (STD) and HIV risk in heterosexual adults attending a public STD clinic: evaluation of a randomized controlled behavioral risk-reduction intervention trial. AIDS. 1997;11(3):359-367. [pmid: 9147428].
539 Golden MR, Rompalo AM, Fantry L, et al. Early intervention for human immunodeficiency virus in Baltimore Sexually Transmitted Diseases Clinics. Impact on gonorrhea incidence in patients infected with HIV. Sex Transm Dis. 1996;23(5):370-377. [pmid: 8885067].
540 Dworkin MS, Ward JW, Hanson DL, et al. Pneumococcal disease among human immunodeficiency virus-infected persons: incidence, risk factors, and impact of vaccination. Clin Infect Dis. 2001;32(5):794-800. [pmid: 11229848].
541 Hirschtick RE, Glassroth J, Jordan MC, et al. Bacterial pneumonia in persons infected with the human immunodeficiency virus. Pulmonary Complications of HIV Infection Study Group. N Engl J Med. 1995;333(13):845-851. [pmid: 7651475].
542 Janoff EN, Tasker SA, Stevenson M, et al. Immune activation and virologic response to immunization in recent HIV type 1 seroconverters. AIDS Res Hum Retroviruses. 1999;15(9):837-845. [pmid: 10381172].
543 Rodriguez-Barradas MC, Alexandraki I, Nazir T, et al. Response of human immunodeficiency virus-infected patients receiving highly active antiretroviral therapy to vaccination with 23-valent pneumococcal polysaccharide vaccine. Clin Infect Dis. 2003;37:438-447. [pmid: 12884170].
544 Kroon FP, van Dissel JT, Ravensbergen E, et al. Antibodies against pneumococcal polysaccharides after vaccination in HIV-infected individuals: 5-year follow-up of antibody concentrations. Vaccine. 1999;18(56):524-530. [pmid: 10519943].
545 Kroon FP, van Dissel JT, de Jong JC, et al. Antibody response to influenza, tetanus and pneumococcal vaccines in HIV-seropositive individuals in relation to the number of CD4+ lymphocytes. AIDS. 1994;8(4):469-476. [pmid: 7912086].
546 Feikin DR, Elie CM, Goetz MB, et al. Randomized trial of the quantitative and functional antibody responses to a 7-valent pneumococcal conjugate vaccine and/or 23-valent polysaccharide vaccine among HIV-infected adults. Vaccine. 2001;20(34):545-553. [pmid: 11672921].
547 Goetz MB, Feikin DR, Lennox JL, et al. Viral load response to a pneumococcal conjugate vaccine, polysaccharide vaccine or placebo among HIV-infected patients. AIDS. 2002;16(10):1421-1423. [pmid: 12131220].
548 Santos J, Palacios R, Ruiz J, et al. Comparative trial of the effect of pneumococcal vaccine on viral load and CD4+ lymphocytes in asymptomatic and antiretrovirally naive HIV-infected patients. Eur J Clin Microbiol Infect Dis. 2002;21(6):488-489. [pmid: 12111612].
549 Negredo E, Domingo P, Sambeat MA, et al. Effect of pneumococcal vaccine on plasma HIV-1 RNA of stable patients undergoing effective highly active antiretroviral therapy. Eur J Clin Microbiol Infect Dis. 2001;20(4):287-288. [pmid: 11399023].
550 French N, Nakiyingi J, Carpenter LM, et al. 23-valent pneumococcal polysaccharide vaccine in HIV-1-infected Ugandan adults: double-blind, randomised and placebo controlled trial. Lancet. 2000;355(9221):2106-2111. [pmid: 10902624].
551 Watera Ca, Nakiyingi Ja, Miiro Ga, et al. 23-Valent pneumococcal polysaccharide vaccine in HIV-infected Ugandan adults: 6-year follow-up of a clinical trial cohort. AIDS. 2004;18(8):1210-1213. [pmid: 15166540].
552 Lindenburg CE, Langendam MW, Benthem BH, et al. No evidence that vaccination with a polysaccharide pneumococcal vaccine protects drug users against all-cause pneumonia. AIDS. 2001;15(10):1315-1317. [pmid: 11426080].
553 Gebo KA, Moore RD, Keruly JC, et al. Risk factors for pneumococcal disease in human immunodeficiency virus-infected patients. J Infect Dis. 1996;173(4):857-862. [pmid: 8603963].
554 Breiman RF, Keller DW, Phelan MA, et al. Evaluation of effectiveness of the 23-valent pneumococcal capsular polysaccharide vaccine for HIV-infected patients. Arch Intern Med. 2000;160(17):2633-2638. [pmid: 10999977].
555 Guerrero M, Kruger S, Saitoh A, et al. Pneumonia in HIV-infected patients: a case-control survey of factors involved in risk and prevention. AIDS. 1999;13:1971-1975. [pmid: 10513657].
556 Zanetti AR, Amendola A, Besana S, et al. Safety and immunogenicity of influenza vaccination in individuals infected with HIV. Vaccine. 2002;20(Suppl 5):B29-32. [pmid: 12477415].
557 Kroon FP, van Dissel JT, de Jong JC, et al. Antibody response after influenza vaccination in HIV-infected individuals: a consecutive 3-year study. Vaccine. 2000;18(26):3040-3049. [pmid: 10825608].
558 King JC Jr, Treanor J, Fast PE, et al. Comparison of the safety, vaccine virus shedding, and immunogenicity of influenza virus vaccine, trivalent, types A and B, live coldadapted, administered to human immunodeficiency virus (HIV)-infected and non-HIV-infected adults. J Infect Dis. 2000;181(2):725-728. [pmid: 10669363].
559 Amendola A, Boschini A, Colzani D, et al. Influenza vaccination of HIV-1-positive and HIV-1-negative former intravenous drug users. J Med Virol. 2001;65(4):644-648. [pmid: 11745926].
560 Huengsberg M, Chakraverty MP, Cooper G, et al. Response to influenza immunisation in asymptomatic HIV infected men. Genitourin Med. 1995;71(6):355-357. [pmid: 8566972]. [pmcid: 1196103].
561 Gunthard HF, Wong JK, Spina CA, et al. Effect of influenza vaccination on viral replication and immune response in persons infected with human immunodeficiency virus receiving potent antiretroviral therapy. J Infect Dis. 2000;181(2):522-531. [pmid: 10669335].
562 Tasker SA, O'Brien WA, Treanor JJ, et al. Effects of influenza vaccination in HIV-infected adults: a doubleblind, placebo-controlled trial. Vaccine. 1998;16(910):1039-1042. [pmid: 9682356].
563 Banic S, Koren S, Tomazic J, et al. Influenza vaccination of human immunodeficiency virus 1-infected patients receiving antiretroviral therapy. Acta Virologica. 2001;45(1):39-44. [pmid: 11394576].
564 Glesby MJ, Hoover DR, Farzadegan H, et al. The effect of influenza vaccination on human immunodeficiency virus type 1 load: a randomized, double-blind, placebo-controlled study. J Infect Dis. 1996;174(6):1332-1336. [pmid: 8940228].
565 Yerly S, Wunderli W, Wyler CA, et al. Influenza immunization of HIV-1-infected patients does not increase HIV-1 viral load. AIDS. 1994;8(10):1503-1504. [pmid: 7818826].
566 Macias J, Pineda JA, Leal M, et al. HIV-1 plasma viremia not increased in patients receiving highly active antiretroviral therapy after influenza vaccination. Eur J Clin Microbiol Infect Dis. 2001;20(1):46-48. [pmid: 11245323].
567 Sullivan PS, Hanson DL, Dworkin MS, et al. Effect of influenza vaccination on disease progression among HIV-infected persons. AIDS. 2000;14(17):2781-2785. [pmid: 11125897].
568 Tasker SA, Treanor JJ, Paxton WB, et al. Efficacy of influenza vaccination in HIV-infected persons. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 1999;131(6):430-433. [pmid: 10498559].
569 Glassroth J, Jordan M, Wallace JM, et al. Use of preventive interventions by persons infected with type-1 human immunodeficiency virus (HIV-1). The Pulmonary Complications of HIV Study Group. Am J Prev Med. 1994;10(5):259-266. [pmid: 7848668].
570 Wortley PM, Farizo KM. Pneumococcal and influenza vaccination levels among HIV-infected adolescents and adults receiving medical care in the United States. Adult and Adolescent Spectrum of HIV Disease Project Group. AIDS. 1994;8(7):941-944. [pmid: 7946103].
571 Kroon FP, van Dissel JT, Rijkers GT, et al. Antibody response to Haemophilus influenzae type b vaccine in relation to the number of CD4+ T lymphocytes in adults infected with human immunodeficiency virus. Clin Infect Dis. 1997;25(3):600-606. [pmid: 9314445].
572 Steinhoff MC, Auerbach BS, Nelson KE, et al. Antibody responses to Haemophilus influenzae type B vaccines in men with human immunodeficiency virus infection. N Engl J Med. 1991;325(26):1837-1842. [pmid: 1683682].
573 Bruguera M, Cremades M, Salinas R, et al. Impaired response to recombinant hepatitis B vaccine in HIV-infected persons. J Clin Gastroenterol. 1992;14(1):27-30. [pmid: 1532609].
574 Tayal SC, Sankar KN. Impaired response to recombinant hepatitis B vaccine in asymptomatic HIV-infected individuals. AIDS. 1994;8:558-559. [pmid: 7912087].
575 Cheeseman SH, Davaro RE, Ellison RT 3rd. Hepatitis B vaccination and plasma HIV-1 RNA. N Engl J Med. 1996;334:1272. [pmid: 8606735].
576 Wong EK, Bodsworth NJ, Slade MA, et al. Response to hepatitis B vaccination in a primary care setting: influence of HIV infection, CD4+ lymphocyte count and vaccination schedule. Int J STD AIDS. 1996;7(7):490-494. [pmid: 9116065].
577 Mannucci PM, Zanetti AR, Gringeri A, et al. Long-term immunogenicity of a plasma-derived hepatitis B vaccine in HIV seropositive and HIV seronegative hemophiliacs. Arch Intern Med. 1989;149(6):1333-1337. [pmid: 2525013].
578 Miller EJ, Lee CA, Karayiannis P, et al. Immune response of patients with congenital coagulation disorders to hepatitis B vaccine: suboptimal response and human immunodeficiency virus infection. J Med Virol. 1989;28(2):96-100. [pmid: 2738584].
579 Rey D, Krantz V, Partisani M, et al. Increasing the number of hepatitis B vaccine injections augments anti-HBs response rate in HIV-infected patients. Effects on HIV-1 viral load. Vaccine. 2000;18(13):1161-1165. [pmid: 10649616].
580 Wilson CM, Ellenberg JH, Sawyer MK, et al. Serologic response to hepatitis B vaccine in HIV infected and high-risk HIV uninfected adolescents in the REACH cohort. Reaching for Excellence in Adolescent Care and Health. J Adolesc Health. 2001;29(3 Suppl):123-129. [pmid: 11530313].
581 Wallace MR, Brandt CJ, Earhart KC, et al. Safety and immunogenicity of an inactivated hepatitis A vaccine among HIV-infected subjects. Clin Infect Dis. 2004;39:1207-1213. [pmid: 15486846].
582 Hess G, Clemens R, Bienzle U, et al. Immunogenicity and safety of an inactivated hepatitis A vaccine in anti-HIV positive and negative homosexual men. J Med Virol. 1995;46(1):40-42. [pmid: 7623005].
583 Neilsen GA, Bodsworth NJ, Watts N. Response to hepatitis A vaccination in human immunodeficiency virus-infected and -uninfected homosexual men. J Infect Dis. 1997;176(4):1064-1067. [pmid: 9333168].
584 Kemper CA, Haubrich R, Frank I, et al. Safety and immunogenicity of hepatitis A vaccine in human immunodeficiency virus-infected patients: a double-blind, randomized, placebo-controlled trial. J Infect Dis. 2003;187(8):1327-1331. [pmid: 12696015].
585 Santagostino E, Gringeri A, Rocino A, et al. Patterns of immunogenicity of an inactivated hepatitis A vaccine in anti-HIV positive and negative hemophilic patients. Thrombosis & Haemostasis. 1994;72(4):508-510. [pmid: 7878624].
586 Bodsworth NJ, Neilsen GA, Donovan B. The effect of immunization with inactivated hepatitis A vaccine on the clinical course of HIV-1 infection: 1-year follow-up. AIDS. 1997;11(6):747-749. [pmid: 9143606].
587 Wallace MR, Hooper DG, Graves SJ, et al. Measles seroprevalence and vaccine response in HIV-infected adults. Vaccine. 1994;12(13):1222-1224. [pmid: 7839728].
588 Kellerman SE, Hanson DL, McNaghten AD, et al. Prevalence of chronic hepatitis B and incidence of acute hepatitis B infection in human immunodeficiency virus-infected subjects. J Infect Dis. 2003;188(4):571-577. [pmid: 12898445].
589 Weber DJ, Rutala WA. Immunization of immunocompromised persons. Immunol Allergy Clin North Am. 2003;23(4):605-634. [pmid: 14753383].
590 Jones JL, Hanson DL, Dworkin MS, et al. HIV-associated tuberculosis in the era of highly active antiretroviral therapy. The Adult/Adolescent Spectrum of HIV Disease Group. Int J Tuberc Lung Dis. 2000;4(11):1026-1031. [pmid: 11092714].
591 Kaplan JE, Hanson D, Dworkin MS, et al. Epidemiology of human immunodeficiency virus-associated opportunistic infections in the United States in the era of highly active antiretroviral therapy. Clin Infect Dis. 2000;30(Suppl 1):S5-14. [pmid: 10770911].
592 Girardi E, Antonucci G, Vanacore P, et al. Impact of combination antiretroviral therapy on the risk of tuberculosis among persons with HIV infection. AIDS. 2000;14(13):1985-1991. [pmid: 10997404].
593 Seage GR 3rd, Losina E, Goldie SJ, et al. The relationship of preventable opportunistic infections, HIV-1 RNA, and CD4 Cell counts to chronic mortality. J Acquir Immune Defic Syndr. 2002;30(4):421-428. [pmid: 12138349].
594 Phair J, Munoz A, Detels R, et al. The risk of Pneumocystis carinii pneumonia among men infected with human immunodeficiency virus type 1. Multicenter AIDS Cohort Study Group. N Engl J Med. 1990;322(3):161-165. [pmid: 1967190].
595 Dworkin MS, Hanson DL, Navin TR. Survival of patients with AIDS, after diagnosis of Pneumocystis carinii pneumonia, in the United States. J Infect Dis. 2001;183(9):1409-1412. [pmid: 11294675].
596 Bucher HC, Griffith L, Guyatt GH, et al. Meta-analysis of prophylactic treatments against Pneumocystis carinii pneumonia and toxoplasma encephalitis in HIV-infected patients. J Acquir Immune Defic Syndr Hum Retrovirol. 1997;15(2):104-114. [pmid: 9241108].
597 Ioannidis JP, Cappelleri JC, Skolnik PR, et al. A metaanalysis of the relative efficacy and toxicity of Pneumocystis carinii prophylactic regimens. Arch Intern Med. 1996;156(2):177-188. [pmid: 8546551].
598 Dworkin MS, Williamson J, Jones JL, et al. Prophylaxis with trimethoprim-sulfamethoxazole for human immunodeficiency virus-infected patients: impact on risk for infectious diseases. Clin Infect Dis. 2001;33(3):393-398. [pmid: 11438910].
599 Murri R, Ammassari A, Pezzotti P, et al. Incidence and determinants of bacterial infections in HIV-positive patients receiving anti-Pneumocystis carinii/Toxoplasma gondii primary prophylaxis within a randomized clinical trial. J Acquir Immune Defic Syndr. 2001;27(1):49-55. [pmid: 11404520].
600 El-Sadr WM, Luskin-Hawk R, Yurik TM, et al. A randomized trial of daily and thrice-weekly trimethoprim-sulfamethoxazole for the prevention of Pneumocystis carinii pneumonia in human immunodeficiency virus-infected persons. Terry Beirn Community Programs for Clinical Research on AIDS (CPCRA). Clin Infect Dis. 1999;29(4):775-783. [pmid: 10589887].
601 Schneider MM, Nielsen TL, Nelsing S, et al. Efficacy and toxicity of two doses of trimethoprim-sulfamethoxazole as primary prophylaxis against Pneumocystis carinii pneumonia in patients with human immunodeficiency virus. J Infect Dis. 1995;171:1632-1636. [pmid: 7769306].
602 El-Sadr WM, Murphy RL, Yurik TM, et al. Atovaquone compared with dapsone for the prevention of Pneumocystis carinii pneumonia in patients with HIV infection who cannot tolerate trimethoprim, sulfonamides, or both. Community Program for Clinical Research on AIDS and the AIDS Clinical Trials Group. N Engl J Med. 1998;339(26):1889-1895. [pmid: 9862944].
603 Payen MC, De Wit S, Sommereijns B, et al. A controlled trial of dapsone versus pyrimethamine-sulfadoxine for primary prophylaxis of Pneumocystis carinii pneumonia and toxoplasmosis in patients with AIDS. Biomed Pharmacother. 1997;51(10):439-445. [pmid: 9863502].
604 Dunne MW, Bozzette S, McCutchan JA, et al. Efficacy of azithromycin in prevention of Pneumocystis carinii pneumonia: a randomised trial. California Collaborative Treatment Group. Lancet. 1999;354(9182):891-895. [pmid: 10489947].
605 Bucher HC, Griffith LE, Guyatt GH, et al. Isoniazid prophylaxis for tuberculosis in HIV infection: a metaanalysis of randomized controlled trials. AIDS. 1999;13(4):501-507. [pmid: 10197379].
606 Wilkinson D. Drugs for preventing tuberculosis in HIV infected persons (Cochrane Review). The Cochrane Library. Chichester, UK: John Wiley & Sons, Ltd.; 2003.
607 Centers for Disease Control and Prevention. Update: Adverse event data and revised American Thoracic Society/CEC recommendations against the use of rifampin and pyrazinamide for treatment of latent tuberculosis infection - United States, 2003. Morb Mortal Wkly Rep. 2003;52(31):735-739.
608 Oldfield EC 3rd, Fessel WJ, Dunne MW, et al. Once weekly azithromycin therapy for prevention of Mycobacterium avium complex infection in patients with AIDS: a randomized, double-blind, placebo-controlled multicenter trial. Clin Infect Dis. 1998;26(3):611-619. [pmid: 9524832].
609 Pierce M, Crampton S, Henry D, et al. A randomized trial of clarithromycin as prophylaxis against disseminated Mycobacterium avium complex infection in patients with advanced acquired immunodeficiency syndrome. N Engl J Med. 1996;335(6):384-391. [pmid: 8663871].
610 Nightingale SD, Cameron DW, Gordin FM, et al. Two controlled trials of rifabutin prophylaxis against Mycobacterium avium complex infection in AIDS. N Engl J Med. 1993;329(12):828-833. [pmid: 8179648].
611 Benson CA, Williams PL, Cohn DL, et al. Clarithromycin or rifabutin alone or in combination for primary prophylaxis of Mycobacterium avium complex disease in patients with AIDS: A randomized, double-blind, placebo-controlled trial. The AIDS Clinical Trials Group 196/Terry Beirn Community Programs for Clinical Research on AIDS 009 Protocol Team. J Infect Dis. 2000;181(4):1289-1297. [pmid: 10762562].
612 Havlir DV, Dube MP, Sattler FR, et al. Prophylaxis against disseminated Mycobacterium avium complex with weekly azithromycin, daily rifabutin, or both. California Collaborative Treatment Group. N Engl J Med. 1996;335(6):392-398. [pmid: 8676932].
613 Moore RD, Chaisson RE. Survival analysis of two controlled trials of rifabutin prophylaxis against Mycobacterium avium complex in AIDS. AIDS. 1995;9(12):1337-1342. [pmid: 8605053].
614 Deayton JR, Sabin CA, Johnson MA, et al. Importance of cytomegalovirus viraemia in risk of disease progression and death in HIV-infected patients receiving highly active antiretroviral therapy. Lancet. 2004;363:2116-2121. [pmid: 15220032].
615 Brosgart CL, Louis TA, Hillman DW, et al. A randomized, placebo-controlled trial of the safety and efficacy of oral ganciclovir for prophylaxis of cytomegalovirus disease in HIV-infected individuals. Terry Beirn Community Programs for Clinical Research on AIDS. AIDS. 1998;12(3):269-277. [pmid: 9517989].
616 Feinberg JE, Hurwitz S, Cooper D, et al. A randomized, double-blind trial of valaciclovir prophylaxis for cytomegalovirus disease in patients with advanced human immunodeficiency virus infection. AIDS Clinical Trials Group Protocol 204/Glaxo Wellcome 123-014 International CMV Prophylaxis Study Group. J Infect Dis. 1998;177(1):48-56. [pmid: 9419169].
617 Spector SA, McKinley GF, Lalezari JP, et al. Oral ganciclovir for the prevention of cytomegalovirus disease in persons with AIDS. Roche Cooperative Oral Ganciclovir Study Group. N Engl J Med. 1996;334(23):1491-1497. [pmid: 8618603].
618 Maiman M, Fruchter RG, Sedlis A, et al. Prevalence, Risk Factors, and Accuracy of Cytologic Screening for Cervical Intraepithelial Neoplasia in Women with the Human Immunodeficiency Virus*1, *2. Gynecol Oncol. 1998;68(3):233-239. [pmid: 9570972].
619 Massad LS, Riester KA, Anastos KM, et al. Prevalence and predictors of squamous cell abnormalities in Papanicolaou smears from women infected with HIV-1. Women's Interagency HIV Study Group. J Acquir Immune Defic Syndr. 1999;21(1):33-41. [pmid: 10235512].
620 Ellerbrock TV, Chiasson MA, Bush TJ, et al. Incidence of cervical squamous intraepithelial lesions in HIV-infected women. JAMA. 2000;283(8):1031-1037. [pmid: 10697063].
621 Massad LS, Ahdieh L, Benning L, et al. Evolution of cervical abnormalities among women with HIV-1: evidence from surveillance cytology in the women's interagency HIV study. J Acquir Immune Defic Syndr. 2001;27(5):432-442. [pmid: 11511819].
622 Davis AT, Chakraborty H, Flowers L, et al. Cervical Dysplasia in Women Infected with the Human Immunodeficiency Virus (HIV): A Correlation with HIV Viral Load and CD4+ Count*1. Gynecol Oncol. 2001;80(3):350-354. [pmid: 11263930].
623 Heard I, Schmitz V, Costagliola D, et al. Early regression of cervical lesions in HIV-seropositive women receiving highly active antiretroviral therapy. AIDS. 1998;12(12):1459-1464. [pmid: 9727566].
624 Orlando G, Fasolo MM, Schiavini M, et al. Role of highly active antiretroviral therapy in human papillomavirus-induced genital dysplasia in HIV-1-infected patients. AIDS. 1999;13(3):424. [pmid: 10199237].
625 Dorrucci M, Suligoi B, Serraino D, et al. Incidence of invasive cervical cancer in a cohort of HIV-seropositive women before and after the introduction of highly active antiretroviral therapy. J Acquir Immune Defic Syndr. 2001;26(4):377-380. [pmid: 11317082].
626 Ioannidis JP, O'Brien TR, Goedert JJ. Evaluation of guidelines for initiation of highly active antiretroviral therapy in a longitudinal cohort of HIV-infected individuals. AIDS. 1998;12(18):2417-2423. [pmid: 9875579].
627 Concorde Coordinating Committee. Concorde: MRC/ANRS randomised double-blind controlled trial of immediate and deferred zidovudine in symptome-free HIV infection. Lancet. 1994;343:871–881.
628 Joint Concorde and Opal Coordinating Committee. Longterm follow-up of randomized trials of immediate versus deferred zidovudine in symptom-free HIV infection. AIDS. 1998;12(11):1259–1265.
629 Darbyshire J, Foulkes M, Peto R, et al. Immediate versus deferred zidovudine (AZT) in asymptomatic or mildly symptomatic HIV infected adults (Cochrane Review). The Cochrane Library. Chichester, UK: John Wiley & Sons, Ltd.; 2003.
630 Ioannidis JP, Cappelleri JC, Lau J, et al. Early or deferred zidovudine therapy in HIV-infected patients without an AIDS-defining illness. Ann Intern Med. 1995;122(11):856-866. [pmid: 7741372].
631 Hammer SM, Squires KE, Hughes MD, et al. A controlled trial of two nucleoside analogues plus indinavir in persons with human immunodeficiency virus infection and CD4 counts of 200 per cubic millimeter or less. N Engl J Med. 1997;337(11):725-733. [pmid: 9287227].
632 Gulick RM, Mellors JW, Havlir D, et al. Treatment with indinavir, zidovudine, and lamivudine in adults with human immunodeficiency virus infection and prior antiretroviral therapy. N Engl J Med. 1997;337(11):734-739. [pmid: 9287228].
633 Cameron DW, Heath-Chiozzi M, Danner S, et al. Randomised placebo-controlled trial of ritonavir in advanced HIV-1 disease. The Advanced HIV Disease Ritonavir Study Group. Lancet. 1998;351(9102):543-549. [pmid: 9492772].
634 Sterling TR, Chaisson RE, Moore RD. HIV-1 RNA, CD4 T-lymphocytes, and clinical response to highly active antiretroviral therapy. AIDS. 2001;15(17):2251-2257. [pmid: 11698698].
635 Hogg RS, Yip B, Chan KJ, et al. Rates of disease progression by baseline CD4 cell count and viral load after initiating triple-drug therapy. JAMA. 2001;286(20):2568-2577. [pmid: 11722271].
636 Kaplan JE, Hanson DL, Cohn DL, et al. When to begin highly active antiretroviral therapy? Evidence supporting initiation of therapy at CD4+ lymphocyte counts <350 cells/microL. Clin Infect Dis. 2003;37(7):951-958. [pmid: 13130408].
637 Lepri AC, Phillips AN, d'Arminio Monforte A, et al. When to start highly active antiretroviral therapy in chronically HIV-infected patients: evidence from the ICONA study. AIDS. 2001;15(8):983-990. [pmid: 11399980].
638 Palella FJ Jr, Deloria-Knoll M, Chmiel JS, et al. Survival benefit of initiating antiretroviral therapy in HIV-infected persons in different CD4+ cell strata. Ann Intern Med. 2003;138(8):620-626. [pmid: 12693883].
639 Ahdieh-Grant L, Yamashita TE, Phair JP, et al. When to initiate highly active antiretroviral therapy: a cohort approach. Am J Epidemiol. 2003;157(8):738-746. [pmid: 12697578].
640 Sterling TR, Chaisson RE, Moore RD. Initiation of highly active antiretroviral therapy at CD4+ T lymphocyte counts of >350 cells/mm3: disease progression, treatment durability, and drug toxicity. Clin Infect Dis. 2003;36(6):812-815. [pmid: 12627368].
641 Anastos K, Barron Y, Miotti P, et al. Risk of progression to AIDS and death in women infected with HIV-1 initiating highly active antiretroviral treatment at different stages of disease. Arch Intern Med. 2002;162(17):1973-1980. [pmid: 12230420].
642 Wood E, Hogg RS, Yip B, et al. Higher baseline levels of plasma human immunodeficiency virus type 1 RNA are associated with increased mortality after initiation of triple-drug antiretroviral therapy. J Infect Dis. 2003;188:1421-1425. [pmid: 14624366].
643 Phillips AN, Lepri AC, Lampe F, et al. When should antiretroviral therapy be started for HIV infection? Interpreting the evidence from observational studies. AIDS. 2003;17(13):1863-1869. [pmid: 12960818].
644 Opravil M, Ledergerber B, Furrer H, et al. Clinical efficacy of early initiation of HAART in patients with asymptomatic HIV infection and CD4 cell count > 350 × 10(6) /l. AIDS. 2002;16(10):1371-1381. [pmid: 12131214].
645 Sterling TR, Chaisson RE, Keruly J, et al. Improved outcomes with earlier initiation of highly active antiretroviral therapy among human immunodeficiency virus-infected patients who achieve durable virologic suppression: longer follow-up of an observational cohort study. J Infect Dis. 2003;188(11):1659-1665. [pmid: 14639536].
646 Wood E, Hogg RS, Yip B, et al. Effect of medication adherence on survival of HIV-infected adults who start highly active antiretroviral therapy when the CD4+ cell count is 0.200 to 0.350 × 10(9) cells/L. Ann Intern Med. 2003;139(10):810-816. [pmid: 14623618].
647 Wang CC, Vlahov D, Galai N, et al. Mortality in HIV-seropositive versus -seronegative persons in the era of highly active antiretroviral therapy: implications for when to initiate therapy. J Infect Dis. 2004;190(6):1046-1054. [pmid: 15319852].
648 Division of AIDS, National Institute of Allergy and Infectious Diseases, National Institutes of Health. The SMART Study - Strategies for Management of Anti-Retroviral Therapy. Available at: http://www.smarttrial.com/. Accessed Nov. 29, 2004.
649 Gartland M, Group AS. AVANTI 3: a randomized, double-blind trial to compare the efficacy and safety of lamivudine plus zidovudine versus lamivudine plus zidovudine plus nelfinavir in HIV-1-infected antiretroviral-naive patients. Antivir Ther. 2001;6(2):127-134. [pmid: 11491417].
650 AVANTI 2. Randomized, double-blind trial to evaluate the efficacy and safety of zidovudine plus lamivudine versus zidovudine plus lamivudine plus indinavir in HIV-infected antiretroviral-naive patients. AIDS. 2000;14(4):367–374.
651 Montaner JS, Reiss P, Cooper D, et al. A randomized, double-blind trial comparing combinations of nevirapine, didanosine, and zidovudine for HIV-infected patients: the INCAS Trial. Italy, The Netherlands, Canada and Australia Study. JAMA. 1998;279(12):930-937. [pmid: 9544767].
652 Raboud JM, Rae S, Hogg RS, et al. Suppression of plasma virus load below the detection limit of a human immunodeficiency virus kit is associated with longer virologic response than suppression below the limit of quantitation. J Infect Dis. 1999;180(4):1347-1350. [pmid: 10479170].
653 Raboud JM, Montaner JS, Conway B, et al. Suppression of plasma viral load below 20 copies/ml is required to achieve a long-term response to therapy. AIDS. 1998;12(13):1619-1624. [pmid: 9764780].
654 Bartlett JA, DeMasi R, Quinn J, et al. Overview of the effectiveness of triple combination therapy in antiretroviral-naive HIV-1 infected adults. AIDS. 2001;15(11):1369-1377. [pmid: 11504958].
655 Ena J, Pasquau F. Once-a-day highly active antiretroviral therapy: a systematic review. Clin Infect Dis. 2003;36(9):1186-1190. [pmid: 12715315].
656 Raffi F, Reliquet V, Podzamczer D, et al. Efficacy of nevirapine-based HAART in HIV-1-infected, treatmentnaive persons with high and low baseline viral loads. HIV Clin Trials. 2001;2(4):317-322. [pmid: 11590534].
657 Kaufmann GR, Perrin L, Pantaleo G, et al. CD4 Tlymphocyte recovery in individuals with advanced HIV-1 infection receiving potent antiretroviral therapy for 4 years: the Swiss HIV Cohort Study. Arch Intern Med. 2003;163(18):2187-2195. [pmid: 14557216].
658 Viard JP, Burgard M, Hubert JB, et al. Impact of 5 years of maximally successful highly active antiretroviral therapy on CD4 cell count and HIV-1 DNA level. AIDS. 2004;18(1):45-49. [pmid: 15090828].
659 Higgins DL, Galavotti C, O'Reilly KR, et al. Evidence for the effects of HIV antibody counseling and testing on risk behaviors. JAMA. 1991;266(17):2419-2429. [pmid: 1920748].
660 Weinhardt LS, Carey MP, Johnson BT, et al. Effects of HIV counseling and testing on sexual risk behavior: a meta-analytic review of published research, 1985-1997. Am J Public Health. 1999;89(9):1397-1405. [pmid: 10474559]. [pmcid: 1508752].
661 Wolitski RJ, MacGowan RJ, Higgins DL, et al. The effects of HIV counseling and testing on risk-related practices and help-seeking behavior. AIDS Educ Prev. 1997;9(Suppl. B):52-67. [pmid: 9241398].
662 Centers for Disease Control and Prevention. Adoption of protective behaviors among persons with recent HIV infection and diagnosis—Alabama, New Jersey, and Tennessee, 1997-1998. Morb Mortal Wkly Rep. 2000;49(23):512-515.
663 Parsons JT, Huszti HC, Crudder SO, et al. Maintenance of safer sexual behaviors: evaluation of a theory based intervention for HIV seropositive men with haemophilia and their female partners. Haemophilia. 2000;6(3):181-190. [pmid: 10792477].
664 Colfax GN, Buchbinder SP, Cornelisse PG, et al. Sexual risk behaviors and implications for secondary HIV transmission during and after HIV seroconversion. AIDS. 2002;16(11):1529-1535. [pmid: 12131191].
665 Darrow W, Webster R, Kurtz S, et al. Impact of HIV counseling and testing on HIV-infected men who have sex with men: the South Beach Health Survey. AIDS Behavior. 1998;2:115-126.
666 Belzer M, Rogers AS, Camarca M, et al. Contraceptive choices in HIV infected and HIV at-risk adolescent females. J Adolesc Health. 2001;29(3 Suppl):93-100. [pmid: 11530309].
667 Murphy DA, Durako SJ, Moscicki AB, et al. No change in health risk behaviors over time among HIV infected adolescents in care: role of psychological distress. J Adolesc Health. 2001;29(3 Suppl):57-63. [pmid: 11530304].
668 Rotheram-Borus MJ, Swendeman D, Comulada S, et al. Prevention for substance-using HIV-positive young people. J Acquir Immune Defic Syndr. 2004;37(2 Suppl):S68-S77. [pmid: 15385902].
669 Rotheram-Borus MJ, Lee MB, Murphy DA, et al. Efficacy of a preventive intervention for youths living with HIV. Am J Public Health. 2001;91(3):400-405. [pmid: 11236404]. [pmcid: 1446609].
670 Kalichman SC, Rompa D, Cage M, et al. Effectiveness of an intervention to reduce HIV transmission risks in HIV-positive people. Am J Prev Med. 2001;21(2):84-92. [pmid: 11457627].
671 Fogarty LA, Heilig CM, Armstrong K, et al. Long-term effectiveness of a peer-based intervention to promote condom and contraceptive use among HIV-positive and at-risk women. Public Health Rep. 2001;116(Suppl 1):103-119. [pmid: 11889279]. [pmcid: 1913678].
672 Coates TJ, McKusick L, Kuno R, et al. Stress Reduction Training Changed Number of Sexual Partners but Not Immune Function in Men with HIV. Am J Public Health. 1989;79(7):885. [pmid: 2735479]. [pmcid: 1349674].
673 Cleary PD, Van Devanter N, Steinlen M, et al. A randomized trial of an education and support program for HIV-infected individuals. AIDS. 1995;9(11):1271-1278. [pmid: 8561981].
674 Patterson TL, Shaw WS, Semple SJ. Reducing the sexual risk behaviors of HIV+ individuals: outcome of a randomized controlled trial. Ann Behav Med. 2003;25(2):137-145. [pmid: 12704016].
675 Richardson JL, Milam J, McCutchan A, et al. Effect of brief safer-sex counseling by medical providers to HIV-1 seropositive patients: a multi-clinic assessment. AIDS. 2004;18(8):1179-1186. [pmid: 15166533].
676 Des Jarlais C, Perlis T, Friedman SR, et al. Behavioral risk reduction in a declining HIV epidemic: injection drug users in New York City, 1990-1997. Am J Public Health. 2000;90(7):1112-1116. [pmid: 10897190]. [pmcid: 1446283].
677 Watters JK. Trends in risk behavior and HIV seroprevalence in heterosexual injection drug users in San Francisco, 1986-1992. J Acquir Immune Defic Syndr. 1994;7(12):1276-1281. [pmid: 7965639].
678 Maslow CB, Friedman SR, Perlis TE, et al. Changes in HIV seroprevalence and related behaviors among male injection drug users who do and do not have sex with men: New York City, 1990-1999. Am J Public Health. 2002;92(3):382-384. [pmid: 11867315]. [pmcid: 1447084].
679 Diaz T, Chu SY, Weinstein B, et al. Injection and syringe sharing among HIV-infected injection drug users: implications for prevention of HIV transmission. Supplement to HIV/AIDS Surveillance Group. J Acquir Immune Defic Syndr Hum Retrovirol. 1998;18(Suppl 1):S76-81. [pmid: 9663628].
680 Calsyn DA, Saxon AJ, Freeman G Jr, et al. Ineffectiveness of AIDS education and HIV antibody testing in reducing high-risk behaviors among injection drug users. Am J Public Health. 1992;82(4):573-575. [pmid: 1546776]. [pmcid: 1694085].
681 McCusker J, Bigelow C, Stoddard AM, et al. Human immunodeficiency virus type 1 antibody status and changes in risk behavior among drug users. Ann Epidemiol. 1994;4(6):466-471. [pmid: 7804502].
682 Margolin A, Avants SK, Warburton LA, et al. A randomized clinical trial of a manual-guided risk reduction intervention for HIV-positive injection drug users. Health Psychol. 2003;22(2):223-228. [pmid: 12683743].
683 Desenclos JC, Papaevangelou G, Ancelle-Park R. Knowledge of HIV serostatus and preventive behaviour among European injecting drug users. AIDS. 1993;7(10):1371-1377. [pmid: 8267911].
684 Schlumberger MG, Desenclos JC, Papaevangelou G, et al. Knowledge of HIV serostatus and preventive behaviour among European injecting drug users: second study. European Community Study Group on HIV in Injecting Drug Users. Eur J Epidemiol. 1999;15(3):207-215. [pmid: 10395049].
685 Celentano DD, Munoz A, Cohn S, et al. Dynamics of behavioral risk factors for HIV/AIDS: a 6-year prospective study of injection drug users. Drug Alcohol Depend. 2001;61(3):315-322. [pmid: 11164696].
686 Ouellet L, Huo D, Bailey SL. HIV risk practices among needle exchange users and nonusers in Chicago. J Acquir Immune Defic Syndr. 2004;37:1187-1196. [pmid: 15319680].
687 O'Brien ME, Clark RA, Besch CL, et al. Patterns and correlates of discontinuation of the initial HAART regimen in an urban outpatient cohort. J Acquir Immune Defic Syndr. 2003;34(4):407-414. [pmid: 14615659].
688 Chen RY, Westfall AO, Mugavero MJ, et al. Duration of highly active antiretroviral therapy regimens. Clin Infect Dis. 2003;37(5):714-722. [pmid: 12942406].
689 Amin J, Moore A, Carr A, et al. Combined analysis of two-year follow-up from two open-label randomized trials comparing efficacy of three nucleoside reverse transcriptase inhibitor backbones for previously untreated HIV-1 infection: OzCombo 1 and 2. HIV Clinical Trials. 2003;4(4):252-261. [pmid: 12916011].
690 Fellay J, Boubaker K, Ledergerber B, et al. Prevalence of adverse events associated with potent antiretroviral treatment: Swiss HIV Cohort Study. Lancet. 2001;358(9290):1322-1327. [pmid: 11684213].
691 Chene G. Cohort studies: what do they tell us?. Journal of HIV Therapy. 2001;6(2):28-31. [pmid: 11501200].
692 Carr A, Samaras K, Thorisdottir A, et al. Diagnosis, prediction, and natural course of HIV-1 protease-inhibitor-associated lipodystrophy, hyperlipidaemia, and diabetes mellitus: a cohort study. Lancet. 1999;353(9170):2093-2099. [pmid: 10382692].
693 Galli M, Ridolfo AL, Adorni F, et al. Body habitus changes and metabolic alterations in protease inhibitor-naive HIV-1-infected patients treated with two nucleoside reverse transcriptase inhibitors. J Acquir Immune Defic Syndr. 2002;29(1):21-31. [pmid: 11782586].
694 Chene G, Angelini E, Cotte L, et al. Role of long-term nucleoside-analogue therapy in lipodystrophy and metabolic disorders in human immunodeficiency virus-infected patients. Clin Infect Dis. 2002;34(5):649-657. [pmid: 11810598].
695 Martinez E, Mocroft A, Garcia-Viejo MA, et al. Risk of lipodystrophy in HIV-1-infected patients treated with protease inhibitors: a prospective cohort study. Lancet. 2001;357(9256):592-598. [pmid: 11558485].
696 Mallal SA, John M, Moore CB, et al. Contribution of nucleoside analogue reverse transcriptase inhibitors to subcutaneous fat wasting in patients with HIV infection. AIDS. 2000;14(10):1309-1316. [pmid: 10930144].
697 Thiebaut R, Dancourt V, Mercie P, et al. Lipdystrophy, metabolic disorders, and human immunodeficiency virus infection: Aquitaine Cohort, France, 1999. Groupe d'Epidemiologie Clinique du Syndrome d'Immunodeficience Acquose en Aquitaine. Clin Infect Dis. 2000;31(6):1482-1487. [pmid: 11096016].
698 Bernasconi E, Boubaker K, Junghans C, et al. Abnormalities of body fat distribution in HIV-infected persons treated with antiretroviral drugs: The Swiss HIV Cohort Study. J Acquir Immune Defic Syndr. 2002;31(1):50-55. [pmid: 12352150].
699 Lichtenstein KA, Ward DJ, Moorman AC, et al. Clinical assessment of HIV-associated lipodystrophy in an ambulatory population. AIDS. 2001;15(11):1389-1398. [pmid: 11504960].
700 Saves M, Raffi F, Capeau J, et al. Factors related to lipodystrophy and metabolic alterations in patients with human immunodeficiency virus infection receiving highly active antiretroviral therapy. Clin Infect Dis. 2002;34(10):1396-1405. [pmid: 11981737].
701 Carr A, Samaras K, Burton S, et al. A syndrome of peripheral lipodystrophy, hyperlipidaemia and insulin resistance in patients receiving HIV protease inhibitors. AIDS. 1998;12(7):F51-58. [pmid: 9619798].
702 Miller KD, Jones E, Yanovski JA, et al. Visceral abdominal-fat accumulation associated with use of indinavir. Lancet. 1998;351(9106):871-875. [pmid: 9525365].
703 Periard D, Telenti A, Sudre P, et al. Atherogenic dyslipidemia in HIV-infected individuals treated with protease inhibitors. The Swiss HIV Cohort Study. Circulation. 1999;100(7):700-705. [pmid: 10449690].
704 Segarra-Newnham M. Hyperlipidemia in HIV-positive patients receiving antiretrovirals. Ann Pharmacother. 2002;36(4):592-595. [pmid: 11918504].
705 Tsiodras S, Mantzoros C, Hammer S, et al. Effects of protease inhibitors on hyperglycemia, hyperlipidemia, and lipodystrophy: a 5-year cohort study. Arch Intern Med. 2000;160(13):2050-2056. [pmid: 10888979].
706 Calza L, Manfredi R, Farneti B, et al. Incidence of hyperlipidaemia in a cohort of 212 HIV-infected patients receiving a protease inhibitor-based antiretroviral therapy. Int J Antimicrob Agents. 2003;22(1):54-59. [pmid: 12842328].
707 Chang ES, Tetreault DD, Liu YT, et al. The effects of antiretroviral protease inhibitors on serum lipid levels in HIV-infected patients. J Am Diet Assoc. 2001;101(6):687-689. [pmid: 11424549].
708 Tashima KT, Bausserman L, Alt EN, et al. Lipid changes in patients initiating efavirenz- and indinavir-based antiretroviral regimens. HIV Clin Trials. 2003;4(1):29-36. [pmid: 12577194].
709 Stein JH, Klein MA, Bellehumeur JL, et al. Use of human immunodeficiency virus-1 protease inhibitors is associated with atherogenic lipoprotein changes and endothelial dysfunction. Circulation. 2001;104(3):257-262. [pmid: 11457741].
710 Thiebaut R, Dequae-Merchadou L, Ekouevi DK, et al. Incidence and risk factors of severe hypertriglyceridaemia in the era of highly active antiretroviral therapy: the Aquitaine Cohort, France, 1996-99. HIV Med. 2001;2(2):84-88. [pmid: 11737383].
711 Heath KV, Chan KJ, Singer J, et al. Incidence of morphological and lipid abnormalities: gender and treatment differentials after initiation of first antiretroviral therapy. Int J Epidemiol. 2002;31(5):1016-1020. [pmid: 12435777].
712 Walli R, Herfort O, Michl GM, et al. Treatment with protease inhibitors associated with peripheral insulin resistance and impaired oral glucose tolerance in HIV-1-infected patients. AIDS. 1998;12(15):F167-173. [pmid: 9468365].
713 Brambilla AM, Novati R, Calori G, et al. Stavudine or indinavir-containing regimens are associated with an increased risk of diabetes mellitus in HIV-infected individuals. AIDS. 2003;17(13):1993-1995. [pmid: 12960836].
714 Dube MP, Edmondson-Melancon H, Qian D, et al. Prospective evaluation of the effect of initiating indinavir-based therapy on insulin sensitivity and B-cell function in HIV-infected patients. J Acquir Immune Defic Syndr. 2001;27(2):130-134. [pmid: 11404534].
715 Dever LL, Oruwari PA, Figueroa WE, et al. Hyperglycemia associated with protease inhibitors in an urban HIV-infected minority patient population. Ann Pharmacother. 2000;34(5):580-584. [pmid: 10852083].
716 Eastone JA, Decker CF. New-onset diabetes mellitus associated with use of protease inhibitor. Ann Intern Med. 1997;127(10):948. [pmid: 9382376].
717 Justman JE, Benning L, Danoff A, et al. Protease inhibitor use and the incidence of diabetes mellitus in a large cohort of HIV-infected women. J Acquir Immune Defic Syndr. 2003;32(3):298-302. [pmid: 12626890].
718 Martinez E, Garcia-Viejo MA, Blanch J, et al. Lipodystrophy syndrome in patients with HIV infection. Drug Saf. 2001;24:157-166. [pmid: 11347720].
719 Blanch J, Rousaud A, Martinez E, et al. Impact of lipodystrophy on the quality of life of HIV-1-infected patients. J Acquir Immune Defic Syndr. 2002;31:404-407. [pmid: 12447011].
720 Saves M, Chene G, Ducimetiere P, et al. Risk factors for coronary heart disease in patients treated for human immunodeficiency virus infection compared with the general population. Clin Infect Dis. 2003;37:292-298. [pmid: 12856222].
721 Rhew DC, Bernal M, Aguilar D, et al. Association between protease inhibitor use and increased cardiovascular risk in patients infected with human immunodeficiency virus: a systematic review. Clin Infect Dis. 2003;37(7):959-972. [pmid: 13130409].
722 Fontas E, van Leth F, Sabin CA, et al. Lipid profiles in HIV-infected patients receiving combination antiretroviral therapy: are different antiretroviral drugs associated with different lipid profiles?. J Infect Dis. 2004;189(6):1056-1074. [pmid: 14999610].
723 Friis-Moller N, Weber R, Reiss P, et al. Cardiovascular disease risk factors in HIV patients—association with antiretroviral therapy. Results from the DAD study. AIDS. 2003;17(8):1179-1193. [pmid: 12819520].
724 Galli M, Cozzi-Lepri A, Ridolfo AL, et al. Incidence of adipose tissue alterations in first-line antiretroviral therapy: the LipoICoNa Study. Arch Intern Med. 2002;162(22):2621-2628. [pmid: 12456235].
725 Saint-Marc T, Partisani M, Poizot-Martin I, et al. A syndrome of peripheral fat wasting (lipodystrophy) in patients receiving long-term nucleoside analogue therapy. AIDS. 1999;13(13):1659-1667. [pmid: 10509567].
726 van der Valk M, Kastelein JJ, Murphy RL, et al. Nevirapine-containing antiretroviral therapy in HIV-1 infected patients results in an anti-atherogenic lipid profile. AIDS. 2001;15(18):2407-2414. [pmid: 11740191].
727 van der Valk M, Gisolf EH, Reiss P, et al. Increased risk of lipodystrophy when nucleoside analogue reverse transcriptase inhibitors are included with protease inhibitors in the treatment of HIV-1 infection. AIDS. 2001;15(7):847-855. [pmid: 11399957].
728 Boufassa F, Dulioust A, Lascaux AS, et al. Lipodystrophy in 685 HIV-1-treated patients: influence of antiretroviral treatment and immunovirological response. HIV Clin Trials. 2001;2(4):339-345. [pmid: 11590538].
729 Joly V, Flandre P, Meiffredy V, et al. Increased risk of lipoatrophy under stavudine in HIV-1-infected patients: results of a substudy from a comparative trial. AIDS. 2002;16(18):2447-2454. [pmid: 12461419].
730 Mauss S, Corzillius M, Wolf E, et al. Risk factors for the HIV-associated lipodystrophy syndrome in a closed cohort of patients after 3 years of antiretroviral treatment. HIV Med. 2002;3(1):49-55. [pmid: 12059951].
731 Shambelan M, Benson CA, Carr A, et al. Management of metabolic complications associated with antiretroviral therapy for HIV-1 infection: recommendations of an International AIDS Society-USA panel. J Acquir Immune Defic Syndr. 2002;31(3):257-275. [pmid: 12439201].
732 Hadigan C, Corcoran C, Basgoz N, et al. Metformin in the treatment of HIV lipodystrophy syndrome: a randomized controlled trial. JAMA. 2000;284(4):472-477. [pmid: 10904511].
733 John M, McKinnon EJ, James IR, et al. Randomized, controlled, 48-week study of switching stavudine and/or protease inhibitors to combivir/abacavir to prevent or reverse lipoatrophy in HIV-infected patients. J Acquir Immune Defic Syndr. 2003;33(1):29-33. [pmid: 12792352].
734 Carr A, Workman C, Smith DE, et al. Abacavir substitution for nucleoside analogs in patients with HIV lipoatrophy: a randomized trial. JAMA. 2002;288(2):207-215. [pmid: 12095385].
735 Carr A, Workman C, Carey D, et al. No effect of rosiglitazone for treatment of HIV-1 lipoatrophy: randomised, double-blind, placebo-controlled trial. Lancet. 2004;363(9407):429-438. [pmid: 14962523].
736 Saint-Marc T, Touraine JL. Effects of metformin on insulin resistance and central adiposity in patients receiving effective protease inhibitor therapy. AIDS. 1999;13(8):1000-1002. [pmid: 10371188].
737 Dube MP, Sprecher D, Henry WK, et al. Preliminary guidelines for the evaluation and management of dyslipidemia in adults infected with human immunodeficiency virus and receiving antiretroviral therapy: Recommendations of the Adult AIDS Clinical Trial Group Cardiovascular Disease Focus Group. Clin Infect Dis. 2000;31(5):1216-1224. [pmid: 11073755].
738 Martinez E, Domingo P, Ribera E, et al. Effects of metformin or gemfibrozil on the lipodystrophy of HIVinfected patients receiving protease inhibitors. Antivir Ther. 2003;8(5):403-410. [pmid: 14640387].
739 Friis-Moller N, Sabin CA, Weber R, et al. Combination antiretroviral therapy and the risk of myocardial infarction. N Engl J Med. 2003;349(21):1993-2003. [pmid: 14627784].
740 Writing Committee of the DAD Study Group. Cardio- and cerebrovascular events in HIV-infected persons. AIDS. 2004;18(13):1811–1817.
741 Law M, Friis-Moller N, Weber R, et al. Modelling the 3-year risk of myocardial infarction among participants in the Data Collection on Adverse Events of Anti-HIV Drugs (DAD) study. HIV Med. 2003;4(1):1-10. [pmid: 12534953].
742 Coplan PM, Nikas A, Japour A, et al. Incidence of myocardial infarction in randomized clinical trials of protease inhibitor-based antiretroviral therapy: an analysis of four different protease inhibitors. AIDS Res Hum Retroviruses. 2003;19(6):449-455. [pmid: 12882653].
743 Holmberg SD, Moorman AC, Greenberg AE. Trends in rates of myocardial infarction among patients with HIV. N Engl J Med. 2004;350(7):730-732. [pmid: 14960752].
744 Holmberg SD, Moorman AC, Williamson JM, et al. Protease inhibitors and cardiovascular outcomes in patients with HIV-1. Lancet. 2002;360(9347):1747-1748. [pmid: 12480430].
745 Barbaro G, Di Lorenzo G, Cirelli A, et al. An open-label, prospective, observational study of the incidence of coronary artery disease in patients with HIV infection receiving highly active antiretroviral therapy. Clin Ther. 2003;25(9):2405-2418. [pmid: 14604740].
746 Mary-Krause M, Cotte L, Simon A, et al. Increased risk of myocardial infarction with duration of protease inhibitor therapy in HIV-infected men. AIDS. 2003;17(17):2479-2486. [pmid: 14600519].
747 Jutte A, Schwenk A, Franzen C, et al. Increasing morbidity from myocardial infarction during HIV protease inhibitor treatment?. AIDS. 1999;13(13):1796-1979. [pmid: 10509592].
748 Leport C, Saves M, Ducimetiere P, et al. Coronary heart disease risk (CHD) in French HIV-infected men started on a protease inhibitor (PI)-containing regimen compared to the general population. [abstract 697-T]. Paper presented at: Ninth Conference on Retroviruses and Opportunistic Infections, February 2002; Seattle, WA.
749 Klein D, Hurley LB, Quesenberry CP Jr, et al. Do protease inhibitors increase the risk for coronary heart disease in patients with HIV-1 infection?. J Acquir Immune Defic Syndr. 2002;30(5):471-477. [pmid: 12154337].
750 Currier JS, Taylor A, Boyd F, et al. Coronary heart disease in HIV-infected individuals. J Acquir Immune Defic Syndr. 2003;33(4):506-512. [pmid: 12869840].
751 Torre D, Pugliese A, Orofino G. Effect of highly active antiretroviral therapy on ischemic cardiovascular disease in patients with HIV-1 infection. Clin Infect Dis. 2002;35(5):631-632. [pmid: 12173141].
752 Bozzette SA, Ake CF, Tam HK, et al. Cardiovascular and cerebrovascular events in patients treated for human immunodeficiency virus infection. N Engl J Med. 2003;348(8):702-710. [pmid: 12594314].
753 Rickerts V, Brodt HR, Staszewski S, et al. Incidence of myocardial infarction in HIV-infected patients between 1983 and 1998: The Frankfurt HIV-Cohort Study. Eur J Med Res. 2000;5(8):329-333. [pmid: 10958765].
754 Braitstein P, Yip B, Heath KV, et al. Interventional cardiovascular procedures among HIV-infected individuals on antiretroviral therapy 1995-2000. AIDS. 2003;17:2071-2075. [pmid: 14502010].
755 Wood E, Hogg RS, Yip B, et al. The impact of adherence on CD4 cell count responses among HIV-infected patients. J Acquir Immune Defic Syndr. 2004;35(3):261-268. [pmid: 15076240].
756 Ickovics JR, Cameron A, Zackin R, et al. Consequences and determinants of adherence to antiretroviral medication: results from Adult AIDS Clinical Trials Group protocol 370. Antivir Ther. 2002;7(3):185-193. [pmid: 12487386].
757 Carrieri MP, Raffi F, Lewden C, et al. Impact of early versus late adherence to highly active antiretroviral therapy on immuno-virological response: a 3-year follow-up study. Antiviral Therapy. 2003;8(6):585-594. [pmid: 14760892].
758 Press N, Tyndall MW, Wood E, et al. Virologic and immunologic response, clinical progression, and highly active antiretroviral therapy adherence. J Acquir Immune Defic Syndr. 2002;31(Suppl 3):S112-117. [pmid: 12562032].
759 Gross R, Bilker WB, Friedman HM, et al. Effect of adherence to newly initiated antiretroviral therapy on plasma viral load. AIDS. 2001;15(16):2109-2117. [pmid: 11684930].
760 Bangsberg DR, Perry S, Charlebois ED, et al. Nonadherence to highly active antiretroviral therapy predicts progression to AIDS. AIDS. 2001;15(9):1181-1183. [pmid: 11416722].
761 Paterson DL, Swindells S, Mohr J, et al. Adherence to protease inhibitor therapy and outcomes in patients with HIV infection. Ann Intern Med. 2000;133(1):21-30. [pmid: 10877736].
762 Sethi AK, Celentano DD, Gange SJ, et al. Association between adherence to antiretroviral therapy and human immunodeficiency virus drug resistance. Clin Infect Dis. 2003;37:1112-1118. [pmid: 14523777].
763 Chesney MA. Factors affecting adherence to antiretroviral therapy. Clin Infect Dis. 2000;30(Suppl 2):S171-176. [pmid: 10860902].
764 Kleeberger CA, Buechner J, Palella F, et al. Changes in adherence to highly active antiretroviral therapy medications in the Multicenter AIDS Cohort Study. AIDS. 2004;18:683-688. [pmid: 15090774].
765 Ickovics JR, Meisler AW. Adherence in AIDS clinical trials: a framework for clinical research and clinical care. J Clin Epidemiol. 1997;50(4):385-391. [pmid: 9179096].
766 Ammassari A, Trotta MP, Murri R, et al. Correlates and predictors of adherence to highly active antiretroviral therapy: overview of published literature. J Acquir Immune Defic Syndr. 2002;31(Suppl 3):S123-127. [pmid: 12562034].
767 Arnsten JH, Demas PA, Grant RW, et al. Impact of active drug use on antiretroviral therapy adherence and viral suppression in HIV-infected drug users. J Gen Intern Med. 2002;17:377-381. [pmid: 12047736]. [pmcid: 1495042].
768 Kalichman SC, Ramachandran B, Catz S. Adherence to combination antiretroviral therapies in HIV patients of low health literacy. J Gen Intern Med. 1999;14(5):267-273. [pmid: 10337035]. [pmcid: 1496573].
769 Haddad M, Inch C, Glazier RH, et al. Patient support and education for promoting adherence to highly active antiretroviral therapy for HIV/AIDS (Cochrane Review). The Cochrane Library. Chichester, UK: John Wiley & Sons, Ltd.; 2003.
770 Knobel H, Carmona A, Lopez JL, et al. Adherence to highly active antiretroviral treatment: impact of individualized assessment. Enferm Infecc Microbiol Clin. 1999;17:78-81. [pmid: 10193067].
771 Rawlings MK, Thompson MA, Farthing CF, et al. Impact of an educational program on efficacy and adherence with a twice-daily lamivudine/zidovudine/abacavir regimen in underrepresented HIV-infected patients. J Acquir Immune Defic Syndr. 2003;34(2):174-183. [pmid: 14526206].
772 Murphy DA, Wilson CM, Durako SJ, et al. Antiretroviral medication adherence among the REACH HIV-infected adolescent cohort in the USA. AIDS Care. 2001;13(1):27-40. [pmid: 11177463].
773 Rogers AS, Miller S, Murphy DA, et al. The TREAT (Therapeutic Regimens Enhancing Adherence in Teens) Program: theory and preliminary results. J Adolesc Health. 2001;29S:30-38. [pmid: 11530301].
774 Delta Coordinating Committee and Virology Group. An evaluation of HIV RNA and CD4 cell count as surrogates for clinical outcome. AIDS. 1999;13(5):565-573. [pmid: 10203381].
775 Staszewski S, DeMasi R, Hill AM, et al. HIV-1 RNA, CD4 cell count and the risk of progression to AIDS and death during treatment with HIV-1 reverse transcriptase inhibitors. AIDS. 1998;12(15):1991-1997. [pmid: 9814867].
776 Hughes MD, Johnson VA, Hirsch MS, et al. Monitoring plasma HIV-1 RNA levels in addition to CD4+ lymphocyte count improves assessment of antiretroviral therapeutic response. ACTG 241 Protocol Virology Substudy Team. Ann Intern Med. 1997;126(12):929-938. [pmid: 9182469].
777 Kim S, Hughes MD, Hammer SM, et al. Both serum HIV type 1 RNA levels and CD4+ lymphocyte counts predict clinical outcome in HIV type 1-infected subjects with 200 to 500 CD4+ cells per cubic millimeter. AIDS Clinical Trials Group Study 175 Virology Study Team. AIDS Res Hum Retroviruses. 2000;16(7):645-653. [pmid: 10791875].
778 Ormaasen V, Bruun JN, Sandvik L, et al. Prognostic value of changes in CD4 count and HIV RNA during the first six months on highly active antiretroviral therapy in chronic human immunodeficiency virus infection. Scand J Infect Dis. 2003;35(67):383-388. [pmid: 12953949].
779 Anastos K, Barron Y, Cohen MH, et al. The prognostic importance of changes in CD4+ cell count and HIV-1 RNA level in women after initiating highly active antiretroviral therapy. Ann Intern Med. 2004;140(4):256-264. [pmid: 14970148].
780 O'Brien WA, Hartigan PM, Daar ES, et al. Changes in plasma HIV RNA levels and CD4+ lymphocyte counts predict both response to antiretroviral therapy and therapeutic failure. VA Cooperative Study Group on AIDS. Ann Intern Med. 1997;126(12):939-945. [pmid: 9182470].
781 O'Brien WA, Hartigan PM, Martin D, et al. Changes in plasma HIV-1 RNA and CD4+ lymphocyte counts and the risk of progression to AIDS. N Engl J Med. 1996;334(7):426-431. [pmid: 8552144].
782 Phillips AN, Eron J, Bartlett J, et al. Correspondence between the effect of zidovudine plus lamivudine on plasma HIV level/CD4 lymphocyte count and the incidence of clinical disease in infected individuals. AIDS. 1997;11(2):169-175. [pmid: 9030363].
783 Katzenstein DA, Hammer SM, Hughes MD, et al. The relation of virologic and immunologic markers to clinical outcomes after nucleoside therapy in HIV-infected adults with 200 to 500 CD4 cells per cubic millimeter. N Engl J Med. 1996;335(15):1091-1098. [pmid: 8813039].
784 Hughes MD, Daniels MJ, Fischl MA, et al. CD4 cell count as a surrogate endpoint in HIV clinical trials: a meta-analysis of studies of the AIDS Clinical Trials Group. AIDS. 1998;12(14):1823-1832. [pmid: 9792383].
785 Hill AM, DeMasi R, Dawson D. Meta-analysis of antiretroviral effects on HIV-1 RNA, CD4 cell count and progression to AIDS or death. Antivir Ther. 1998;3(3):139-145. [pmid: 10682131].
786 Tovanabutra S, Robison V, Wongtrakul J, et al. Male viral load and heterosexual transmission of HIV-1 subtype E in Northern Thailand. J Acquir Immune Defic Syndr. 2002;29:275-283. [pmid: 11873077].
787 Fiore JR, Zhang YJ, Bjorndal A, et al. Biological correlates of HIV-1 heterosexual transmission. AIDS. 1997;11(9):1089-1094. [pmid: 9233454].
788 Ragni MV, Faruki H, Kingsley LA. Heterosexual HIV-1 transmission and viral load in hemophilic patients. J Acquir Immune Defic Syndr Hum Retrovirol. 1998;17:42-45. [pmid: 9436757].
789 Pedraza M-A, del Romero J, Roldan F, et al. Heterosexual transmission of HIV-1 is associated with high plasma viral load levels and a positive viral isolation in the infected partner. J Acquir Immune Defic Syndr. 1999;21(2):120-125. [pmid: 10360803].
790 O'Brien TR, Busch MP, Donegan E, et al. Heterosexual transmission of human immunodeficiency virus type 1 from transfusion recipients to their sex partners. J Acquir Immune Defic Syndr. 1994;7(7):705-710. [pmid: 8207648].
791 Weller S, Davis K. Condom effectiveness in reducing heterosexual HIV transmission (Cochrane Review). The Cochrane Library. Chichester, UK: John Wiley & Sons, Ltd.; 2004.
792 Pinkerton SD, Abramson PR. Effectiveness of condoms in preventing HIV transmission. Soc Sci Med. 1997;44(9):1303-1312. [pmid: 9141163].
793 Des Jarlais DC, Friedmann P, Hagan H, et al. The protective effect of AIDS-related behavioral change among injection drug users: a cross-national study. WHO Multi-Centre Study of AIDS and Injecting Drug Use. Am J Public Health. 1996;86(12):1780-1785. [pmid: 9003137]. [pmcid: 1380733].
794 Gibson DR, Flynn NM, Perales D. Effectiveness of syringe exchange programs in reducing HIV risk behavior and HIV seroconversion among injecting drug users. AIDS. 2001;15(11):1329-1341. [pmid: 11504954].
795 Gibson DR, Flynn NM, McCarthy JJ. Effectiveness of methadone treatment in reducing HIV risk behavior and HIV seroconversion among injecting drug users. AIDS. 1999;13(14):1807-1818. [pmid: 10513638].
796 Centers for Disease Control and Prevention. Cluster of HIV-infected adolescents and young adults—Mississippi, 1999. Morb Mortal Wkly Rep. 2000;49:861-864.
797 Centers for Disease Control and Prevention. HIV transmission among black college student and non-student men who have sex with men—North Carolina, 2003. Morb Mortal Wkly Rep. 2004;53(32):731-734.
798 Bisson G, Gross R, Miller V, et al. Monitoring of long-term toxicities of HIV treatments: an international perspective. AIDS. 2003;17:2407-2417. [pmid: 14600511].
799 McQuillan GM, Khare M, Karon JM, Schable CA, Vlahov D. Update on the seroepidemiology of human immunodeficiency virus in the United States household population: NHANES III, 1988-1994. J Acquir Immune Defic Syndr Hum Retrovirol. 1997;14(4):355-360. [pmid: 9111478].
800 Lemp GF, Hirozawa AM, Givertz D, et al. Seroprevalence of HIV and risk behaviors among young homosexual and bisexual men. The San Francisco/Berkeley Young Men's Survey. JAMA. 1994;272(6):449-454. [pmid: 8040980].
801 Maruschak LM. HIV in Prisons, 2001: Bureau of Justice Statistics Bulletin, U.S. Department of Justice, Office of Justice Programs; 2004.
802 Sabin CA, Fisher M, Churchill D, et al. Long-term follow-up of antiretroviral-naive HIV-positive patients treated with nevirapine. J Acquir Immune Defic Syndr. 2001;26(5):462-465. [pmid: 11391166].
803 Weinstock H, Dale M, Linley L, Gwinn M. Unrecognized HIV infection among patients attending sexually transmitted disease clinics. Am J Public Health. 2002;92(2):280-283. [pmid: 11818306]. [pmcid: 1447057].
804 Rothman RE, Ketlogetswe KS, Dolan T, Wyer PC, Kelen GD. Preventive care in the emergency department: should emergency departments conduct routine HIV screening? A systematic review. Acad Emerg Med. 2003;10:278-285. [pmid: 12615596].
805 Janssen RS, St Louis ME, Satten GA, et al. HIV infection among patients in U.S. acute care hospitals. Strategies for the counseling and testing of the hospital patients. The Hospital HIV Surveillance Group. N Engl J Med. 1992;327(7):445-452. [pmid: 1625734].
806 Reichler MR, Bur S, Reves R, et al. Results of testing for human immunodeficiency virus infection among recent contacts of infectious tuberculosis cases in the United States. Int J Tuberc Lung Dis. 2003;7(12 Suppl 3):S471-478. [pmid: 14677840].
807 Glynn SA, Kleinman SH, Schreiber GB, et al. Trends in incidence and prevalence of major transfusion-transmissible viral infections in US blood donors, 1991 to 1996. JAMA. 2000;284:229-235. [pmid: 10889598].
808 Sateren WB, Renzullo PO, Carr JK, Birx DL, McNeil JG. HIV-1 infection among civilian applicants for US military service, 1985-2000: epidemiology and geography. J Acquir Immune Defic Syndr. 2003;2003:215-222. [pmid: 12571533].
809 Renzullo PO, Sateren WB, Garner RP, Milazzo MJ, Birx DL, McNeil JG. HIV-1 seroconversion in United States Army active duty personnel, 1985-1999. AIDS. 2001;15(12):1569-1574. [pmid: 11504990].
810 Coplan PM, Nikas AA, Leavitt RY, et al. Indinavir did not increase the short-term risk of adverse cardiovascular events relative to nucleoside reverse transcriptase inhibitor therapy in four phase III clinical trials. AIDS. 2001;15(12):1584-1586. [pmid: 11504995].