# Discussion

## Summary of Evidence

There is no direct evidence on benefits of screening for HIV infection in the general population. Other evidence obtained for the systematic review is summarized in Table 12. It indicates the type of study design and the quality of evidence for each key question.

Table 12 Summary of Findings of Systematic Evidence Review

Arrow | Key question | Level and type of evidence | Overall evidence for the link | Findings
1 | Does screening for HIV in asymptomatic adolescents and adults reduce premature death and disability or spread of disease? | None | Not applicable | No controlled studies or observational studies link screening directly to health outcomes.
2 | Can clinical or demographic characteristics (including specific settings) identify subgroups of asymptomatic adolescents and adults at increased risk for HIV compared to the general population? | II-2. Cohort and cross-sectional studies | Good | The strongest risk factors for HIV infection from multiple large observational studies are intravenous drug use, male to male sex, and high risk sexual behaviors. The largest U.S. study found that in federally funded testing sites, 20% to 26% of HIV-positive patients reported no risk factors. In high-risk settings, several observational studies found that targeted screening patients based on broad criteria could increase the yield of screening, but would still miss 7% to 13% of positive patients while testing a much higher proportion.
3 | What are the test characteristics of HIV antibody test strategies? | Studies of diagnostic test accuracy | Good for standard and Oraquick rapid test; | Standard testing is associated with a sensitivity and specificity of >99%. Initial studies indicate that FDA-approved rapid tests are associated with similar diagnostic test accuracy, but data from clinical settings is limited for rapid tests other than Oraquick on blood specimens. Home sampling and oral specimen sampling appear to have diagnostic accuracy comparable to standard testing, but urine specimens may be associated with lower accuracy.
| | | Fair for other testing and collection methods
4 | What are the harms (including labeling and anxiety) associated with screening? Is screening acceptable to patients? | Studies of diagnostic test accuracy | Good for false-positive rates and false-negative rates; | False-positive results appear rare with standard testing, even in low prevalence settings (1 out of 250,000 blood donors). False-positive tests from rapid tests could occur if results are given prior to confirmatory testing.
| | II-2. Cohort and cross-sectional studies for harms of screening and acceptability | Fair to good for harms from screening and acceptability of testing | False-negative results could occur during the window period before seroconversion and provide false reassurance. True-negative tests could also provide false reassurance in patients practicing high-risk behaviors.
| | | | True-positive tests are associated with social consequences, anxiety, and labeling, but these harms are difficult to measure. Violence occurs at a high frequency in HIV-infected persons, but the impact of screening is not clear. In larger or more recent observational studies, disclosure has not clearly been shown to increase partner dissolution, intimate partner violence, or suicide risk.
| | | | Acceptance rates vary widely even within similar settings (10% to 97%) and may be improved by the availability of newer screening methods (rapid tests, non-invasive samples, home-based collection, on-site testing). An opt-out testing policy increased testing rates in one study.
5 | How many newly diagnosed HIV-positive patients meet criteria for antiretroviral treatment or prophylaxis for opportunistic infections? How many patients who meet criteria for interventions receive them? | II-2. Cohort and cross-sectional studies | Fair for proportion of patients qualifying for intervention at treatment (little information on initial viral load); | Seven U.S. studies found that 12% to 43% of patients are diagnosed with CD4 counts below 200 cells/mm^3^, and 46% to 80% with CD4 counts below 500 cells/mm^3^. There were no studies reporting initial CD4 counts and viral loads in asymptomatic patients. There were no studies estimating the effects of screening on the proportion of patients qualifying for interventions, or the effects of HAART on the proportion of patients qualifying for prophylaxis.
| | | Good for proportion diagnosed late; | A significant proportion of HIV-positive patients do not receive or decline care. Observational studies found that 7% to 47% of intravenous drug users incorrectly self-reported negative status; 36% to 63% of infected patients were estimated to be receiving care at least once every six months in 1996; 38% to 58% with positive tests don't return for initial posttest counseling (though about 90% are eventually located) and 53% to 85% of infected patients who met guidelines for antiretroviral treatment were receiving them.
| | | Fair for long-term consequences of late diagnosis | Two studies found that 26% to 27% of patients are diagnosed concurrently with HIV and AIDS, and three recent U.S. studies found that 37% to 43% of patients are diagnosed with AIDS within 1 year of HIV diagnosis.
| | | | Patients with lower CD4 counts and higher viral loads appear to have poorer response to antiretroviral therapy, but data on long-term outcomes are lacking.
6 | What are the harms associated with the work-up for HIV infection? | None | Not applicable | No evidence.
7a | 1) How effective is antiretroviral treatment in improving clinical outcomes (mortality, functional status, quality of life, symptoms, opportunistic infections, or transmission rates)? | I, II-2. Randomized controlled trials, large cohort studies | Good for clinical outcomes; | HAART is associated with improved clinical outcomes (clinical progression and death) compared to two drug therapy (OR 0.62, 95% CI 0.51–0.70) and other less-intense regimens. Numerous large cohort studies consistently found a marked decrease in clinical progression or death on HAART. Differences in clinical outcomes from different HAART regimens have not been shown in head-to-head trials. Quality of life outcomes from HAART have not been well studied in clinical trials. Beneficial effects of HAART on reducing horizontal transmission by lowering viral load may be offset by increases in risky behaviors, but there was insufficient evidence to estimate the effects of HAART on transmission rates.
| | | Fair for quality of life and spread of disease
7a | 2) How effective is counseling on risky behaviors in reducing transmission rates? | II. Cohort studies | Fair | There is little data on the effects of counseling and testing on HIV transmission rates in the U.S. In Africa, knowledge of HIV-positive status of their male partner was associated with a reduction in transmission by about 50% to uninfected women. Several observational studies indicate that sexually transmitted disease rates decline in persons following HIV-diagnosis, but may increase in persons testing negative. Interactive HIV counseling and testing was more effective than standard didactic counseling and testing in reducing sexually transmitted disease rates in one large, good-quality randomized trial, though there were too few cases to determine whether it was more effective at reducing new HIV infections. There is insufficient evidence to estimate effects of counseling on drug behaviors and transmission rates.
7a | 3) How effective are immunizations in improving clinical outcomes? | I, II-2. Randomized controlled trials, large cohort studies | Fair for pneumococcal, influenza, and hepatitis B vaccinations; | In one randomized trial from Uganda, pneumococcal vaccination was associated with an increased risk of all-cause pneumonia (HR 1.89, 95% CI 1.1–3.2), though long-term follow-up found an unexpected survival advantage (HR 0.84, 95% CI 0.7–1.0). Observational studies mostly found a benefit from vaccination, particularly in patients with higher CD4 counts.
| | | Poor for others | Influenza vaccination was associated with a lower risk of respiratory symptomatic illness (49% vs. 29%; p=0.04) in a clinical trial of HIV-infected patients in a military clinic.
| | | | Hepatitis B vaccination was associated with a lower risk of acute hepatitis B infection in one observational study of HIV-infected persons. There are no studies with clinical outcomes of other immunizations in HIV-positive patients.
7a | 4) How effective is routine monitoring and follow-up in improving clinical outcomes? | None | Not applicable | No evidence.
7a | 5) How effective is prophylaxis for opportunistic infections in improving clinical outcomes? | I, II-2. Randomized controlled trials, large cohort studies | Good overall | Good-quality systematic reviews found that chemoprophylaxis for pneumocystis carinii pneumonia reduced the risk of PCP (RR 0.39, 95% CI 0.27–0.55) and was associated with a nonsignificant mortality benefit (RR 0.87, 95% CI 0.60–1.25). Some medications effective for PCP prophylaxis were also effective for toxoplasmosis prophylaxis. A good-quality systematic review found that prophylaxis was effective at preventing active tuberculosis (risk reduced by 60–86%) and death (risk reduced by 21–23%) in patients with a positive skin test. Multiple randomized controlled trials found that chemoprophylaxis was effective for preventing disseminated mycobacterium avium intracellulare infection, and may be associated with a mortality benefit (HR around 0.75). In three randomized trials, prophylaxis for cytomegalovirus in patients who are CMV-antibody positive may prevent invasive CMV-disease, but does not appear associated with a significant mortality benefit.
7a | 6) How effective is more frequent Papanicolaou testing in improving clinical outcomes? | None | Not applicable | No clinical trials or observational studies estimating the effects of more intense cervical cancer screening in HIV-infected women.
7b | In asymptomatic patients with HIV infection, does immediate antiviral treatment result in improvements in clinica outcomes compared to delayed treatment until symptomatic? | II-2. Cohort studies | Fair | Large observational studies that controlled for lead-time bias consistently found that starting HAART at CD4 counts above 350 cells/mm^3^ is associated with better clinical outcomes than starting below 200 cells/mm^3^. The optimal CD4 count at which to start HAART in patients with CD4 counts between 200 and 350 cells/mm^3^ is unclear. Observational studies that have controlled for lead-time bias did not control for other potentially important confounders (such as level of adherence or physician experience).
7c | How well do interventions reduce the rate of viremia, improve CD4 counts, or reduce risky behaviors? | I, II-2. Randomized clinical trials and large cohort studies | Good | A fair-quality systematic review of HAART regimens found a rate of viral load suppression <50 copies/ml at 48 weeks of 47% overall (95% CI, 43–51%). Numerous good-quality head-to-head clinical trials of different HAART regimens reported rates of undetectable viremia ranging from 21% to 83%. Observational studies found that 40–50% of patients reached and maintained CD4 counts >500 cells/mm^3^ on HAART after 4–5 years, and 47% had a viral load <50 copies/ml after six years.
| | | | Two good-quality systematic reviews found that HIV counseling and testing are associated with decreases in risky sexually behaviors in persons testing positive, but the strength of the association varied according to the group studied. The strongest association was in heterosexual couples and in those testing positive. More intense counseling was more effective than standard counseling in several randomized trials.
8 | What are the harms associated with antiretroviral therapy? | I, II-2. Randomized clinical trials and large cohort studies | Good | In numerous clinical trials and observational studies, HAART regimens were associated with significant short-term adverse events. Many patients can be switched to effective alternative regimens. Specific antiretroviral drugs and combinations are associated with specific adverse event profiles. A large, good-quality prospective cohort study found that the incidence of myocardial infarction and cardiac or cerebrovascular events increased with longer exposure to HAART (adjusted relative risk per year 1.26 [95% CI 1.12–1.41] and 1.26 [95% CI 1.14–1.38] respectively) for the first 4 years, but the overall rate was low at 3.5 and 5.7 events respectively per 1000 person-years. Estimates of adherence range from 50% to 70% but studies used different methods to measure adherence and define of nonadherence.
9 | Have improvements in intermediate outcomes (CD4 counts, viremia, risky behaviors) been shown to reduce premature death and disability and spread of disease? | I, II-2. Randomized controlled trials and large cohort studies | Good for CD4 count or viral load and clinical progression and transmission risk; | Clinical trials and a large collaborative analysis of 13 cohort studies found that 6-month CD4 count and viral load were strongly independently associated with clinical outcomes in patients starting HAART.
| | | Fair for behavior changes and transmission risk | Observational studies found that low viral load was strongly correlated with decreased risk of HIV transmission in heterosexual couples, but data from patients treated with HAART are lacking.
| | | | Condoms have been shown to be associated with decreased risk of transmission from HIV-infected persons. In mixed populations of infected and uninfected drug users, lower rates of HIV infection were associated with decreased risky drug use behaviors, participation in needle exchange programs, and participation in drug treatment programs.

## Outcomes Table

The yield and outcomes of HIV screening will differ according to the prevalence of HIV infection in the population screened. Table 13 estimates the outcomes from one-time screening for HIV after 3 years in three hypothetical cohorts of 10,000 adolescents or adults (the general population, in a setting with 1% prevalence, and in high-risk persons), using the most applicable and highest quality available evidence. We limited our time horizon to 3 years because longer studies on the clinical benefits from HAART are not yet available. We excluded areas from this table in which reliable data to estimate the clinical magnitude of benefit or harm were not available, such as harms from screening (anxiety, labeling, violence, suicide, partnership dissolution) and decreased transmission from counseling or other interventions. We also had insufficient data to estimate the impact of screening on earlier diagnosis of HIV and the proportion of patients qualifying for different interventions. Because short-term adverse events from HAART are usually self-limited, and effective alternative regimens are usually available, we focused on the long-term cardiovascular harms of HAART. We calculated the relative risk for myocardial infarction and cardio- or cerebrovascular events (myocardial infarction, stroke, or invasive cardiovascular procedures) after two to four years on HAART from data reported from the largest, prospective study on cardiovascular complications from combination antiretroviral therapy (Appendix 5).^739,^ ^740^ Because there are no clinical trials directly comparing clinical outcomes from HAART compared to no treatment, we calculated this relative risk from data reported in a good-quality systematic review of trials of three- versus two-drug regimens, two- versus one-drug regimens, and one-drug regimens versus placebo or no treatment, using a fixed-effects model.^421^ We calculated numbers needed to screen and treat to prevent one case of clinical progression (new category B or C event^1^) or death and to cause one cardiovascular event. There was insufficient data from clinical trials to separate clinical outcomes by severity.

Table 13 Outcomes Table of Counseling and One-Time Screening for HIV Infection After Three Years in 10,000 Asymptomatic Adolescents and Adults

Variable | Average-risk population | Prevalence 1% | High-risk | Source
Base-case assumptions
Prevalence of HIV infection | 0.3% | 1% | 5–15% | CDC, 2002^403^
| | | | McQuillan, 1997^799^
| | | | Valleroy, 2000^182^
| | | | Holmberg, 1996^181^
Yield of partner notification (newly diagnosed HIV per index patient) | 0.08–0.23 | 0.08–0.23 | 0.08–0.23 | Macke, 1999^234^
| | | | CDC, 2003^235^
Accuracy of standard testing | 99%+ | 99%+ | 99%+ | Weber, 1995^240^
| | | | McAlpine, 1994^241^
| | | | CDC, 1990^237^
| | | | CDC, 1988^145^
Proportion of HIV-positive patients who receive test results | 79–93% | 79–93% | 79–93% | Erickson, 1990^218^
| | | | Hightow, 2003^376^
| | | | CDC, 2004^225^
| | | | Molitor, 1999^375^
Proportion of patients who would qualify for treatment (assuming only patients with CD4 count <200 cells/mm3 treated) | 12–43% | 12–43% | 12–43% | Samet, 2001^348^
| | | | Katz, 1992^349^
| | | | Luby, 1994^350^
| | | | Hutchinson, 1991^351^
| | | | Klein, 2003^212^
Proportion of patients qualifying for antiretroviral therapy who would receive it | 53–85% | 53–85% | 53–85% | Stall, 2001^383^
| | | | Cunningham, 2000^384^
| | | | Kaplan, 1999^385^
| | | | McNaghten, 2003^386^
3-year risk of clinical progression or death in untreated patients with CD4 count <200 cells/mm3 | 86% (95% CI 77%–93%) | 86% (95% CI 77%–93%) | 86% (95% CI 77%–93%) | Mellors, 1997^87^
Relative risk for clinical progression or death with HAART compared to no treatment | 0.35 (95% CI 0.25–0.47) | 0.35 (95% CI 0.25–0.47) | 0.35 (95% CI 0.25–0.47) | Calculated from Jordan 2002^421^ using random effects model
Background rate of myocardial infarction (cases per 3 person-years) | 0.00158 (95% CI 0.000508–0.00487) | 0.00158 (95% CI 0.000508–0.00487) | 0.00158 (95% CI 0.000508–0.00487) | Calculated from Friis-Moller 2003,^739^ Figure 1
Relative risk for myocardial infarction with HAART after 2–4 years compared to no treatment | 7.73 (95% CI 2.42–24.71) | 7.73 (95% CI 2.42–24.71) | 7.73 (95% CI 2.42–24.71) | Calculated from Friis-Moller 2003,^739^ Figure 1
Background rate of cardio- or cerebrovascular (myocardial infarction, stroke, or invasive cardiovascular procedure) events (cases per 3 person-years) | 0.00368 (95% CI 0.00175–0.00770) | 0.00368 (95% CI 0.00175–0.00770) | 0.00368 (95% CI 0.00175–0.00770) | Calculated from Writing Group of the DAD Study 2004,^740^ Figure 1
Relative risk for cardio or cerebrovascular events with HAART after 2–4 years compared to no treatment | 5.00 (95% CI 2.31–10.82) | 5.00 (95% CI 2.31–10.82) | 5.00 (95% CI 2.31–10.82) | Calculated from Writing Group of the DAD Study 2004,^740^ Figure 1
Relative risk for spread of disease | Unable to estimate | Unable to estimate | Unable to estimate
Results
Number screened | 10000 | 10000 | 10000
Number identified as positive | 30 | 100 | 500–1500
Number receiving test results | 23.7–27.9 | 79–93 | 395–1395
Partners identified as HIV-positive | 1.90–6.42 | 6.3–21.4 | 31.6–321
Total number of HIV-positive patients identified | 25.6–34.3 | 85–114 | 426–1716
Number with CD4 count <200 cells/mm^3^ | 3.07–14.8 | 10.2–49.2 | 51–738
Number with CD4 count <200 cells/mm^3^ who would progress without treatment after 3 years | 2.6 (95% CI 2.4–2.9) – 12.6 (95% CI 11.5–13.8) | 8.8 (95% CI 8.0–9.6) – 42 (95% CI 38–46) | 44 (95% CI 40–49) – 636 (95% CI 576–692)
Number receiving antiretroviral treatment | 1.63–12.5 | 5.4–41.8 | 27–627
Clinical progression or death prevented over 3 years with HAART | 0.9 (95% CI 0.7–1.1) – 7.0 (95% CI 5.6–8.2) | 3.0 (95% CI 2.4–3.6) – 23.3 (95% CI 18.6–27.5) | 15.1 (95% CI 12.1–17.8) – 350 (95% CI 279–412)
Number needed to screen to prevent 1 clinical progression or death over 3 years | 1430 (95% CI 1213– 1792) – 11018 (95% CI 9348–13804) | 429 (95% CI 364–538) –3306 (2804–4145) | 29 (95% CI 24–36) – 661 (95% CI 560–829)
Number needed to treat with HAART to prevent 1 clinical progression or death over 3 years | 1.8 (95% CI 1.5–2.2) | 1.8 (95% CI 1.5–2.2) | 1.8 (95% CI 1.5–2.2)
Numbers need to counsel, screen, or treat to prevent 1 horizontal transmission over 3 years | Unable to calculate | Unable to calculate | Unable to calculate
Background number of myocardial infarctions in patients receiving antiretroviral therapy over 3 years | 0.003 (95% CI 0.0008–0.008) – 0.020 (95% CI 0.006–0.06) | 0.008 (95% CI 0.003–00026) – 0.066 (95% CI 0.02–0.20) | 0.04 (95% CI 0.01–0.13) – 0.99 (95% CI 0.3–3.1)
Myocardial infarctions caused by HAART over 3 years | 0.02 (95% CI 0.002–0.09) – 0.13 (95% CI 0.02–0.73) | 0.06 (95% CI 0.008– 0.31) – 0.44 (95% CI 0.06–2.43) | 0.28 (95% CI 0.04–1.6) – 6.55 (95% CI 1.0– 36)
Number needed to screen to cause 1 myocardial infarction over 3 years | 76330 (95% CI 13730–507100) – 588080 (95% CI 105790–3907130) | 22850 (95% CI 4100–152950) – 176050 (95% CI 31580–1178480) | 1520 (95% CI 270–10250) – 35250 (95% CI 6340–236880)
Number needed to treat with HAART to cause 1 myocardial infarction over 3 years | 96 (95% CI 17–636) | 96 (95% CI 17–636) | 96 (95% CI 17–636)
Background number of cardio- or cerebrovascular events in patients receiving antiretroviral therapy over 3 years | 0.006 (95% CI 0.003–0.01) – 0.05 (95% CI 0.02–0.10) | 0.02 (95% CI 0.01–0.04) – 0.15 (95% CI 0.07– 0.3) | 0.1 (95% CI 0.05–0.2) – 2.3 (95% CI 1.1–4.8)
Cardio- or cerebrovascular events caused by HAART over 3 years | 0.02 (95% CI 0.006–0.08) – 0.2 (95% CI 0.05–0.6) | 0.08 (95% CI 0.02– 0.26) – 0.6 (95% CI 0.2–2.0) | 0.4 (95% CI 0.1–1.3) – 9.13 (95% CI 2.4–30)
Number needed to screen to cause 1 cardio- or cerebrovascular event over 3 years | 54740 (95% CI 16860–205130) – 421770 (95% CI 129890–1580520) | 16410 (95% CI 510– 61570) – 126450 (95% CI 39030– 474410) | 1100 (95% CI 340–4110) – 25310 (95% CI 7790–94980)
Number needed to treat with HAART to cause 1 cardio- or cerebrovascular event over 3 years | 69 (95% CI 21–257) | 69 (95% CI 21–257) | 69 (95% CI 21–257)

Several assumptions made our estimates on the benefits of screening conservative. First, we focused on the effects of HAART. For some interventions (such as most immunizations, more frequent Papanicolaou testing, surveillance, and counseling), there was insufficient data to estimate the magnitude of benefit. For others, such as prophylaxis for opportunistic infections, the magnitude of benefit from HAART substantially outweighs the benefit from other interventions, and successful treatment with HAART would also reduce the proportion of patients requiring prophylaxis by increasing CD4 counts. Second, we assumed that only asymptomatic patients with CD4 counts less than 200 cells/mm3 would routinely receive HAART, as they are at highest risk for clinical progression, evidence regarding clinical benefits of treatment is strongest in this group, and recommendations are less firm for asymptomatic patients with higher CD4 counts. Third, we only estimated benefits for the first 3 years after screening, though HAART is likely to be beneficial beyond that time period.

Numbers needed to screen to prevent one case of clinical progression or death after three years ranged from 1,210 to 13,800 in the general population to 24 to 830 in high-risk patients. Numbers needed to screen to cause one myocardial infarction ranged from 13,700 to 3,907,100 in the general population to 270 to 236,900 in high-risk patients, and numbers needed to screen to cause one cardio- or cerebrovascular event (myocardial infarction, stroke, or invasive cardiovascular procedure) ranged from 16,900 to 1,580,500 in the general population to 340 to 95,000 in high-risk patients. The estimated number needed to treat with HAART to prevent one case of clinical progression or death was 1.8 (95% CI, 1.5 to 2.2), the number needed to treat to cause one myocardial infarction was 96 (95% CI, 17 to 636), and the number needed to treat to cause one cardio- or cerebrovascular event was 69 (95% CI, 21 to 257).

## Conclusions

HIV screening can accurately identify infected persons. Risk factor assessment can identify persons at increased risk of infection, but would miss a significant number of infected persons. Identification and treatment of asymptomatic HIV infection at immunologically advanced stages of disease can result in marked reductions in clinical progression and mortality. There is insufficient evidence to estimate the effects of screening or treatment with HAART on HIV transmission rates. HIV counseling appears effective in reducing risky behaviors in persons testing positive and serodiscordant heterosexual couples, but evidence for other groups is inconclusive. The estimated three-year benefits of HAART appear to greatly outweigh the cardiovascular complications, but longer follow-up is needed. Screening is likely to be beneficial in average-risk persons, but the yield from screening in higher-prevalence (≥1%) populations with prevalence would be substantially higher than the yield from screening in the general population (prevalence 0.3%). Data are insufficient to accurately estimate the benefits (reduced clinical progression or spread of disease) from identifying asymptomatic persons at earlier stages of disease.

## Limitations of the Literature

In assessing the balance of benefits and harms from screening for HIV infection, we highlight several areas of key uncertainties:

Population screened. Reasonable screening strategies might be to screen all patients with acknowledged risk factors, all patients in settings with a high prevalence of HIV infection, or all patients in the general population. Studies that have assessed the usefulness of risk factor assessment to guide screening indicate that targeted screening misses a significant proportion of HIV-positive patients, even when broad criteria to guide targeted screening are used. On the other hand, universal screening of low-risk patients would result in large numbers of patients counseled and tested for each clinical outcome prevented. Even if voluntary screening were offered to all patients, a substantial proportion of patients would decline testing, particularly in low-risk settings. Methods to improve risk assessment methods and screening acceptance rates have not been well studied. Although about half of new HIV infections are acquired before age 25 and this population may pose unique challenges,^796^ studies of youth-friendly approaches to HIV counseling and testing, and methods to improving testing rates are lacking.

Currently recommended HIV counseling prior to testing and subsequent follow-up require substantial resources. More abbreviated or streamlined counseling methods could encourage providers to offer screening and patients to accept it, but studies evaluating their impact are not yet available. There are currently no clinical data to guide frequency of screening in high- or low-risk populations.

Screening methods. The effect of newer testing and sampling methods (rapid tests, home-based sampling, noninvasive sampling, on-site testing) on acceptance of testing and rates of patient notification of results has only been evaluated in a few studies. Polymerase chain reaction testing of pooled specimens to identify acutely infected persons who would test negative by conventional testing appears feasible, but is not yet in widespread use. Broader application of these techniques to clinical settings would help clarify their role in screening.

Harms from screening. Anecdotal reports of violence, suicide, partnership dissolution, and other adverse effects from screening are concerning, but data to estimate the magnitude of these harms are limited. Good-quality studies on methods to minimize the risk of these harmful outcomes are also lacking.

Interventions. HAART is clearly effective in improving clinical outcomes in HIV-infected persons diagnosed with immunologically advanced disease. On the other hand, there is inadequate evidence to accurately estimate the benefits from interventions in patients at earlier stages of disease. Widespread screening could lead to the identification of a higher proportion of patients who would not initially qualify for HAART or other interventions based on their CD4 count or viral load, and other interventions such as counseling and routine monitoring and follow-up would assume greater relative importance. The case for screening, particularly in lower-risk populations, would be greatly strengthened by data showing that identification in earlier, asymptomatic stages of disease is associated with decreased transmission rates. The relationship between HAART use, increased risky behaviors, and transmission rates also needs to be explored further. The optimal timing of HAART in asymptomatic patients remains unresolved at CD4 counts between 350 and 200 cells/mm3, and there is little evidence to guide the use of viral load measurements for initiating therapy. Studies on effective methods to promote entry into care and use of effective interventions are lacking, particularly in specific target populations such as adolescents and minorities. Studies evaluating effects of different HAART regimens on quality of life, an important outcome in patients who may be maintained on treatment for years, are also lacking. Most clinical trials of HAART have also excluded adolescents. The beneficial effects of counseling on reducing risky behaviors have mostly been shown in serodiscordant heterosexual couples, and substantial gaps regarding the effects of counseling in specific subgroups such as intravenous drug users, men who have sex with men, women, adolescents, and minority populations^107^ remain.

## Future Research

Studies measuring clinical outcomes from screening for HIV infection in low-risk settings would require large populations with long duration of follow-up, and may not be feasible. In order to estimate the effects of screening on the stage at which patients are diagnosed and the proportion of patients qualifying for different interventions, studies evaluating the effects of different screening strategies on the initial CD4 count and viral load at which patients are diagnosed would be very helpful. Further studies of rapid tests, polymerase chain reaction testing of pooled samples to identify acutely infected persons, and other newer testing methods will help clarify their role in different settings. Studies evaluating methods to resolve barriers to testing and increase notification of results and entry into care are a priority, as attaining the maximum potential benefits of screening require that HIV-positive patients be both properly identified and receive appropriate care. As HIV is acquired prior to age 25 in approximately one-half of infected persons, studies evaluating methods to improve testing rates and entry into care for this population are especially needed. Studies evaluating the effects of counseling to reduce risky behaviors targeted at specific populations such as illicit drug users, adolescents or young adults,^797^ and ethnic minorities are also a high priority. Studies of the effects of streamlined counseling on testing rates and notification of results would help clarify its role in screening, particularly in low-risk populations.

Additional trials to determine the optimal HAART regimen and longer-term follow-up of patients on HAART therapy remain a priority. Trials of HAART that include adolescents are lacking and should be strongly considered, as effective early treatment in this population could have substantial long-term effects on clinical outcomes and disease transmission. Particular attention to adverse events as patients are maintained on HAART will help identify emerging or unexpected long-term harms.^798^ Studies evaluating methods to maximize adherence rates to HAART and other interventions could help maximize their potential effectiveness. The results of the SMART trial will add substantial information regarding the optimal timing of HAART in asymptomatic patients.

HIV incidence rates have remained steady in the U.S. over the last decade. Studies measuring the effects of counseling on transmission rates, particularly in patients at earlier stages who don't qualify for HAART or other interventions, are a high priority. In addition, studies further evaluating the complex interaction between antiretroviral treatment, viral suppression and risky behaviors will help clarify mechanisms of continued transmission despite the widespread use of HAART.