# Results

## Key Question 1. Does Screening for HIV Infection in Asymptomatic Adolescents and Adults Reduce Premature Death and Disability or Spread of Disease?

We identified no randomized trials or observational studies comparing clinical outcomes between patients in the general population screened and not screened for HIV.

## Key Question 2. Can Clinical or Demographic Characteristics (Including Specific Settings) Identify Subgroups of Asymptomatic Adolescents and Adults at Increased Risk for HIV Compared to the General Population?

The 1996 USPSTF recommendations defined persons at increased risk of HIV infection as those seeking treatment for sexually transmitted diseases;^39,^ ^40,^ ^177^–^179^ men who have had sex with men after 1975;^180^–^182^ past or present injection drug users;^178,^ ^183^–^185^ persons who exchange sex for money or drugs^186^–^189^ and their sex partners;^190,^ ^191^ women and men whose past or present sex partners were HIV-infected,^192^ bisexual individuals, or injection drug users; and persons with a history of transfusion between 1978 and 1985.^126^ Current CDC guidelines also consider unprotected vaginal or anal intercourse with more than one sex partner a high risk behavior, and recommend screening in certain high-risk or high-prevalence (>1%) settings (Table 1).^126,^ ^193^ Risk factors for HIV in adolescents and adults are similar, and appear unchanged since 1996.^194^–^199^ A recent increase in the number of new HIV diagnoses appears primarily attributable to an increase among men who have sex with men.^6^

Large U.S. studies reporting the prevalence of HIV infection in the general population and selected subpopulations and settings are summarized in Table 2. In 2002, new diagnoses of HIV or AIDS in the U.S. were associated with male-to-male sex in 42% of persons, heterosexual contact in 35%, intravenous drug use in 17%, intravenous drug use by men who have sex with men in 3.8%, and other risk factors in 2%.^6^ Among females, the most prevalent exposure categories were heterosexual contact (76.7%) and injection drug use (20.3%). Among males, the most prevalent exposure categories were men who have sex with men (59.7%), heterosexual contact (17.8%) and injection drug use (15.8%). Since the adoption of effective screening techniques, blood product transfusions are no longer an important mode of transmission.^200,^ ^201^ The majority of new HIV diagnoses in the U.S. are among non-Hispanic blacks and account for 71.8% of diagnoses in females and 48.6% in males.^6^ Between 1999 and 2002, the number of new HIV diagnoses rose most rapidly (by 26%) among Hispanics. The incidence of HIV infection is rising particularly rapidly among young minority women.^202^

Table 2 Estimates of Prevalence of HIV Infection in The General U.S. Population and Selected High-Risk Populations and Settings

Setting and source | Date of estimate | Prevalence | Source
General population
National surveillance estimates | 2002 | 0.3% | CDC, 2002^403^
Household based sample | 1988-1994 | 0.3%; 95% confidence interval 0.2% to 0.5% | McQuillan, 1997^799^ (NHANES III)
Men who have sex with men
4 metropolitan areas | 1997 | 17%; 95% confidence interval 15% to 19% | Catania, 2001^180^
23 sexually transmitted disease clinics | 1993-1997 | 26%; range 8% to 39% | CDC, 2001^178^
96 metropolitan areas with populations >500,000 | up to 1994 | 18.3% | Holmberg, 1996^181^
Young men who have sex with men
194 public venues frequented by young (15 to 22 years old) men who have sex with men | 1994-1998 | 7.2% (overall); range 2.2% to 12.1% | Valleroy, 2000^182^
| | 16% (black men); range 13% to 18% | CDC, 2002^5^
26 locations in San Francisco and Berkeley frequented by young (17 to 22 years old) men who have sex with men | 1992-1993 | 9.4%; 95% confidence interval 6.8% to 12.6% | Lemp, 1994^800^
Intravenous drug users
22 drug treatment centers in 13 metropolitan areas | 1993-1997 | 19%; range 1% to 36% | CDC, 2001^178^
96 metropolitan areas with populations >500 000 | up to 1994 | 14.0% | Holmberg, 1996^181^
High-risk heterosexual behavior
23 sexually transmitted disease clinics | 1993-1997 | 2.3%; range 0.3% to 5.5% | CDC, 2001^178^
96 metropolitan areas with populations >500 000 | up to 1994 | 2.3% | Holmberg, 1996^181^
Persons identified through partner notification of HIV-infected persons
Systematic review of 5 U.S. studies | up to 1995 | Range 10% to 25% | Macke, 1999^234^
State of North Carolina | 2001 | 20% | CDC, 2003^235^
Correctional facilities
All inmates in state and federal prisons | 2001 | 1.9% known to be infected in 2001 | Maruschak, 2004^801^
48 correctional facilities throughout the U.S. | 1992-1998 | 3.4% of those accepting voluntary testing positive | Sabin, 2001^802^
Sexually transmitted disease clinics
Sexually transmitted disease clinics in 4 urban counties in the Western U.S. | 1998-1999 | Range 0.33% to 0.95% for heterosexual men, 0.30% to 0.86% for women, and 8.6% to 21% for men who have sex with men | Harawa, 2004^179^
28 sexually transmitted disease clinics in 14 cities | 1997 | Range 0.6% to 11.5%; median 4.7% | Weinstock, 2002^803^
Emergency rooms
8 studies assessing prevalence in emergency rooms | Studies published 1993-1999 | Range 2% to 14% | Rothman, 2003^804^
Acute care hospitals
20 hospitals in 15 cities | 1989-1991 | 4.7%; range 0.2% to 14.2% | Janssen, 1992^805^
Tuberculosis clinics
Patients with active pulmonary tuberculosis at 5 state and big city health departments | 1996 | 27% | Reichler, 2003^806^
Federally funded HIV testing programs | 1993 | 2.1% | Peterman, 1996^193^
Close contacts of persons with active pulmonary tuberculosis
5 state and big city health departments | 1996 | 9% | Reichler, 2003^806^
Homeless adults and runaway youths
16 state and local health departments | 1989-1992 | Range 0% to 21.1%; median 3.3% | Allen, 1994^197^
Adolescent health clinics
5 adolescent health clinics in 3 metropolian areas | 1993-1997 | 0.4%; range 0.2% to 0.5% | CDC, 2001^178^
22 adolescent health clinics | 1990-1992 | 0.2%; range 0% to 1.4% | Sweeney, 1995^198^
Blood donors
First-time American Red Cross blood donors | 1997 | 0.032% for men, 0.021% for women | CDC, 2001^178^
First-time blood donors at 5 blood centers across the United States | 1991-1996 | 0.030% (1991) to 0.015% (1996) | Glynn, 2000^807^
Military applicants
All persons applying for active duty or reserve military service | 2000 | 0.036% | Sateren, 2003^808^
Active duty military
All active duty U.S. Army personnel | 1985-1999 | 0.13% | Renzullo, 2001^809^

A significant proportion of Americans report behaviors that could put them at risk for HIV infection. A recent large survey found that 13% to 19% of persons in 4 U.S. cities reported unprotected intercourse with partners of unknown or HIV-negative status.^203^ Another recent U.S. phone survey (n=33,913) found that 11% of sexually active respondents reported multiple sexual partners within the last 12 months and 4.2% reported other high-risk behaviors.^204^ Approximately one-half of teens were sexually active in a 1995 survey, and among those 29% of females and 19% of males had recent unprotected recent intercourse.^205^ Rates of condom use were lower in black or Hispanic compared to white teens.^206^ Injection drug users, men who have sex with men, and persons attending sexually transmitted disease clinics report a high rate of recent risky behaviors that put them at increased risk for acquiring HIV such as needle sharing, multiple sexual partners, and not always using condoms.^207^

Most adolescents^208^ and adults^209^ appear willing to discuss and disclose high risk behaviors when asked about them.^210,^ ^211^ Even in settings with good access, however, high-risk behaviors might remain undetected or might not lead to testing. One study of a managed care clinic found that 86% of 440 newly diagnosed HIV-positive patients were eventually found to have identifiable risk factors, but only 26% had risk factors documented in the chart before diagnosis.^212^ Another study found that although patients with a new HIV diagnosis had a median of five prior clinical visits and most had testing triggers identified during one or more visits, HIV was addressed in only 27% of these encounters.^213^

The largest U.S. study measuring the proportion of HIV-infected persons reporting no risk factors used data from 1,281,606 clients tested at 2,027 federally funded HIV testing sites.^193^ It found that the proportion of positive clients who reported no risk factors ranged from 26% (1,875 of 7,281) at sites with a prevalence greater than or equal to 5 percent, to 20% (1,477 of 7,208) at sites with a prevalence of 0.1%–2.0%. The rate of HIV positivity in patients reporting no risk factors ranged from 0.2% to 0.8% in the low-prevalence sites and 1.4% to 5.7% in the high-prevalence sites.

We identified three studies in high-risk settings that evaluated the yield of different methods to target screening. One study that prospectively evaluated different risk assessment methods found that among STD clinic patients, only testing those reporting risky behaviors would have resulted in 5.8% being tested and 74% (79/107) missed diagnoses.^214^ Also testing patients with specific high-prevalence demographic characteristics (black males and age >30 years) would have resulted in 70% being tested and 8% (9/107) missed diagnoses. Two retrospective studies in emergency room^215^ and mental hospital^216^ settings also found that screening strategies targeted to persons reporting risky behaviors and specific high-prevalence demographic groups would have been the most efficient, resulting in 33% to 41% of the population being tested and 7% (1/14)^216^ to 13% (192/1,474)^215^ missed diagnoses.

Other retrospective studies have reported that 26% to 51% of patients in STD clinics,^217^–^219^ 26% of emergency room patients,^220^ 38% of adolescent health clinic patients,^221^ 14% of patients in a managed care setting,^212^ 17% of patients in a low prevalence (0.26%) hospital,^222^ and 7% to 24% of tuberculosis clinic patients^223,^ ^224^ found to be HIV-positive reported no risk factors. Factors that may explain some of the variation in rates of identifiable risk factors include population differences, varying stringency of risk factor ascertainment, or broadening of what is included as an HIV risk factor (e.g., number of partners or unprotected heterosexual intercourse).

The yield of routine voluntary screening compared to targeted screening has primarily been evaluated in higher-risk settings. Implementation of routine voluntary HIV screening with oral sampling in four urgent care centers in high-prevalence cities in Massachusetts resulted in 32% of 10,352 persons being tested and an HIV prevalence of 2.0% (60/3,068) among those tested.^225^ In Georgia, implementation of routine voluntary HIV screening with rapid or standard testing in an urgent care center resulted in 24% of 10,719 patients being tested (more than double the previous year), an increase in the number of newly detected infections (74 vs. 47), and twice as many HIV-positive patients who entered into care (26 vs. 13).^226^ Another study in a high-prevalence (>1%) urban hospital found that rates of testing after implementing a routine voluntary testing policy increased from 2.0% to 6.4% (473/7,356), and the number of positive tests increased from 1.3 to 2.3 per month.^227^ In an emergency room setting, 1.8% of 8,635 adults were voluntarily tested, and 3.2% (5/155) newly diagnosed with HIV infection.^228^ In an older study at an average-risk hospital, 51% (4535 of 8868) patients agreed to voluntary testing, and 0.26% (12 of 4535) tested positive.^222^ Ten of the twelve HIV-positive persons (83%) were considered high-risk.

In several studies that performed blinded seroprevalence testing, the rate of HIV infection was higher in those that declined voluntary testing than in those who accepted it.^222,^ ^229^–^231^ In a large observational study of 14 STD clinics with a mean voluntary testing rate of 61%, for example, the rate of unreported HIV-seropositivity among persons who declined testing was 4.8% using blinded seroprevalence surveys, compared to 2.0% among those tested.^231^

After identification of an index case of HIV through screening, voluntary partner counseling and referral services (PCRS) can identify additional persons at risk for infection.^232,^ ^233^ We identified one good-quality systematic review that found that the additional number of HIV-infected persons identified through provider-initiated PCRS in the U.S. ranged from 0.08 to 0.23 per index case in five studies.^234^ A recent large study from the state of North Carolina found that the yield of partner notification was 0.08 (125 infected partners identified from 1580 index cases).^235^

## Key Question 3. What are the Test Characteristics of HIV Antibody Test Strategies?

### Conventional tests

The use of repeatedly reactive enzyme immunoassay (EIA) followed by confirmatory Western Blot (WB) or immunofluorescent assay (IFA) is the standard method for diagnosing HIV-1 infection. ^236,^ ^237^ One good quality systematic review of 26 studies of EIA tests available prior to 1989 found a wide range of sensitivities (89% – 100%) and specificities (67% – 100%) prior to confirmatory testing.^238^ A subsequent study of HIV testing in 752 U.S. laboratories reported a sensitivity of 99.7% and specificity of 98.5%; a study of 290,000 low-risk blood donors in Minnesota reported a specificity of >99.99%, and a specificity of 99.8% was consistently reported during screening of donated blood in the American Red Cross Blood Services laboratories.^145,^ ^237,^ ^239^ Despite the very high accuracy of newer EIA tests,^240,^ ^241^ confirmatory testing of positive results with Western blot is still required because even a specificity of over 99% is associated with a higher than desired false-positive rate in low-prevalence populations.^145^

Although the Western blot detects the same antibodies as EIA, it must demonstrate specific banding patterns to be considered positive.^146^ Banding patterns that do not meet positive or negative criteria are indeterminate and require further evaluation.^242^ The rate of EIA-reactive, indeterminate Western blot tests varies according to the immunoblot used, the prevalence of HIV-1 infection in the population tested, and the interpretive criteria used, but is estimated to range between 4% and 20%.^243^ Reasons for indeterminate Western blot include overlapping antibody patterns with other disease entities such as lymphoma, multiple sclerosis, liver disease, or autoimmune disorders; or a blood test drawn during early seroconversion. In blood donors with indeterminate tests who did not shortly seroconvert, the rate of later HIV infection was 0 out of 355 in one study.^244^

### Alternative testing and sampling methods

Alternative screening technologies such as rapid testing, home-based testing, or non-invasive sampling (urine and saliva) may increase the acceptability of testing or rates of post-test counseling and entry into medical care.^126,^ ^243,^ ^245,^ ^246^ Rapid tests, for example, can be performed within 10–30 minutes, making them useful for point-of-care testing, such as for patients attending emergency departments who do not receive regular medical care, or in other settings in which on-site results may increase access to timely treatment.^247^

### Rapid tests

The Food and Drug Administration (FDA) has approved four rapid HIV tests. Only two of these tests (Uni-Gold and OraQuick) have been granted a Clinical Laboratory Improvement Amendments (CLIA) waiver from the FDA. This designation approves them for true point-of-care testing performed at the bedside, with results available in approximately 10–30 minutes. The remaining FDA-approved rapid tests (Reveal and SUDS) must be performed in a laboratory. Manufacture of the SUDS test was discontinued in 2003. Although most studies of the OraQuick test evaluated older versions approved for whole blood specimen testing (OraQuick Rapid HIV-1 Antibody Test and OraQuick Rapid HIV-1/2 Antibody Test), a newer version (OraQuick ADVANCE Rapid HIV-1/2 Antibody Test) was recently approved for use with oral as well as whole blood specimens.

We identified three good and ten fair quality studies evaluating the test characteristics of the three FDA-approved rapid HIV antibody tests currently available in the U.S. (Table 3). Of these, ten were studies only reported in manufacturer inserts.^248^–^250^ Most studies that were rated fair quality did not adequately describe the patient population studied or had potential spectrum bias. Because patients are often notified of rapid HIV test results before leaving the testing site, some could be informed of false-positive results before confirmatory test results are available. Most studies therefore measured the diagnostic accuracy of rapid tests before confirmatory testing, though CDC guidelines recommend routine confirmation of positive rapid tests.^251^ The reference standard in all studies was standard HIV testing.

Table 3 Test Characteristics of Rapid HIV-1 Antibody Tests Currently Available in The U.S

Test | N | Sensitivity | Specificity | Quality | Source
OraQuick | 5744 | 100 (90–100) | 99.9 (99.78–99.98) | GOOD | Bulterys, 2004^252^
| 334 | 100 | 100 | GOOD | Reynolds, 2002^253^
| 201 | 96 | 100 | GOOD | O'Connell, 2003^254^
| 625 | 100 | 100 | FAIR | OraQuick Package Insert^250^
| | | | Inadequate description of patient population
| 521 | 99.6 | | FAIR | OraQuick Package Insert^250^
| | | | Inadequate description of patient population
| 1250 | | 100 | FAIR | OraQuick Package Insert^250^
| | | | Inadequate description of patient population
UniGold | 1000 | 100 | 99.8 (99.2–100) | FAIR | UniGold Package Insert^249^
| | | | Inadequate description of population
| 1032 | 100 (99.5–100) | | FAIR | UniGold Package Insert^249^
| | | | Inadequate description of population
| 1000 | | 99.7 (99.0–100) | FAIR | UniGold Package Insert^249^
| | | | Inadequate description of population
Reveal | 483 | 100 | | FAIR | Reveal Package Insert^248^
| | | | Inadequate description of population
| 2914 | 99.2 | | FAIR | Reveal Package Insert^248^
| | | | Inadequate description of population
| 850 | | 99.4 | FAIR | Reveal Package Insert^248^
| | | | Inadequate description of population
| 2789 | | 99.1 | FAIR | Reveal Package Insert^248^
| | | | Inadequate description of population

Blank cells indicate study was not designed to calculate this value.

We identified three good^252^–^254^ and three fair quality^250^ studies evaluating the test characteristics of OraQuick rapid HIV testing. In one good-quality prospective study of 5,744 U.S. women (prevalence 0.59%) presenting during labor, sensitivity was 100%, specificity 99.9%, the positive predictive value 90%, and negative predictive value 100% for OraQuick HIV-1.^252^ A good-quality prospective cohort study of low risk Air Force volunteers and persons with known HIV-infection found a sensitivity of 96% and specificity of 100% when OraQuick HIV-1 was applied to whole blood and oral mucosal transudates.^254^ False negative test results were associated with lower HIV viral load and longer duration of HAART use. A good-quality African study of primarily non-B HIV subtypes found OraQuick HIV-1/2 had a sensitivity and specificity of 100%.^253^ Three fair-quality studies using OraQuick HIV-1 found sensitivities that ranged from 99.6% to 100%, with specificity 100% in all studies.^250^.

For the Uni-Gold Recombigen and Reveal tests, fair-quality studies reported sensitivities ranging from 94% to 100%, and specificities greater than 99% (Table 3).^248,^ ^249^ A study evaluating an earlier version of the Uni-Gold rapid test found a sensitivity of 96% and specificity of 88%.^255^ Four good quality studies of the SUDS test (FDA-approved but no longer being manufactured) found sensitivities and specificities ranging from 99.3% to 100% and 92% to 99.5%, respectively.^255^–^258^

### Other testing or sampling methods

The Epitope OraSure HIV-1 Oral Specimen Collection Device (Epitope, Inc.) is a device that collects oral fluid for HIV testing. Two large good-quality studies evaluated the test characteristics of the OraSure collection device in conjunction with FDA-approved oral fluid EIA and Western blot testing.^259,^ ^260^ In a study of 3,570 U.S. subjects with a wide spectrum of presentations (prevalence 18.9%), oral mucosal sampling with the Orasure collection device had a sensitivity of 99.9% (672/673) and specificity of 99.9% (2,893/2,897) compared to standard testing.^259^ In a good-quality study of 4,422 blood donors and patients attending HIV testing clinics in Trinidad and Tobago (prevalence 10.7%), sensitivity was 99.2%, specificity 99.2%, positive predictive value 93.4%, and negative predictive value 99.9% compared with standard testing.^260^ Other studies of non-FDA-approved oral sampling devices or tests primarily performed in developing countries found sensitivities of 32% to 100% and specificities of 84% to 100%.^245^

Urine HIV tests have also been FDA-approved, but the sensitivity and specificity has generally been found to be lower than standard testing, and they are not in widespread use in the U.S.^245,^ ^261^–^263^

The FDA has approved home collection sampling for HIV testing. In contrast to true home-based testing, which is not FDA-approved, home collection sampling require that the specimen be sent in for laboratory testing, and the patient notified of results. A good-quality study of the only FDA-approved home collection kit (Home Access) found that the sensitivity and specificity were both 100% compared to standard testing in 1,255 subjects (prevalence 13%) using finger-stick blood spot samples.^264^ 98% of the subjects were able to successfully obtain a sample. Another study found that 99% of dried blood spot and oral fluid specimens were adequate for testing.^265^

Conventional testing for HIV infection is not able to detect recently infected persons who have not yet seroconverted, and are thought to be more contagious.^67^ A recent U.S. study found that testing pooled EIA-negative specimens from 8,155 persons undergoing routine HIV screening with an ultra-sensitive polymerase chain reaction test (with follow-up individual testing of positive pooled specimens) identified four acute infections and increased the yield of testing by about 10%.^266^ There was one false positive, and the specificity of this strategy was 99.99%. The estimated cost per additional case diagnosed was $4,109.

### Frequency of testing

We identified no studies evaluating the optimal frequency of HIV screening in high or low-risk populations. The optimal frequency of screening would depend in part on the incidence of new infections in the group being tested and the prevalence of undetected HIV infection.^267^ In one study of repeat testing among persons attending sexually transmitted disease clinics, the incidence rates ranged from 0.81 to 7.0 new infections/100 person-years among men who have sex with men, to 0.018 to 1.2 infections/100 person-years among heterosexual men and women.^268^ A large observational study (over 2.5 million tests) found that re-tested persons with a previously negative result had lower rates of HIV-positivity compared to those not previously tested,^193^ but other studies found that repeatedly negative testers reported particularly high-risk behaviors.^269^–^271^

## Key Question 4. What are the Harms (Including Labeling and Anxiety) Associated with Screening? Is Screening Acceptable to Patients?

### False-positive and false-negative rates

False-positive results from standard HIV testing appear rare, even in low-prevalence settings. One study of over 5 million blood donors found a false-positive rate of 1 in 250,000 (95% CI, 1 in 173,000 to 1 in 379,000).^272^ Other information regarding the frequency and consequences (anxiety, labeling) of false-positive and indeterminate test results are mostly anecdotal.^273^–^275^ False-negative results that occur during the window period before seroconversion and true-negative results could provide false reassurance if tested persons continue to practice high-risk behaviors.

The only study evaluating the false-positive rate of rapid HIV testing in a clinical setting in the U.S. was a good-quality study of 5,744 pregnant women presenting to labor and delivery units with unknown HIV status (prevalence 0.59%) which found a positive predictive value of 90% and negative predictive value of 100% using the OraQuick blood test.^252^ In this study, four false-positive rapid tests resulted in initiation of unnecessary antiretroviral therapy that was discontinued after confirmatory test results became available. Patients undergoing rapid testing could also be incorrectly informed that they had a false-positive result. CDC postmarketing surveillance data from 14 state and local health departments identified five persons with a positive OraQuick test and discordant initial confirmatory test results who may have been notified that their initial test was a false-positive, but developed evidence of HIV infection on follow-up testing.^251^

For other rapid tests, the estimated positive predictive value in different prevalence settings can be calculated from available sensitivity and specificity data, but the actual positive predictive values may differ. For the Reveal, Uni-Gold, and SUDS tests, the positive predictive values were estimated at 25% to 50% in settings with a prevalence of 0.3%, and 85% to 95% in settings with a prevalence of 5%.^276^ The positive predictive value of the OraQuick test was estimated to remain near 100% even in low-prevalence settings.

### Other harms from screening

True-positive HIV tests are associated with important potential harms. Recent large surveys indicates that a significant proportion (20% to 25%) of persons in the U.S. agree with statements that indicate stigmatizing attitudes towards HIV, though the proportion has declined since the early 1990's.^277,^ ^278^ Patients diagnosed with HIV report fears of rejection, abandonment, verbal abuse, and physical assault.^279^ Four percent of 142 recently diagnosed HIV-infected patients reported losing a job because of their HIV status, 1% had been asked to move by a landlord, and 1% assaulted.^280^

Earlier studies reported a high level of affective and adjustment disorders following notification, including high suicide rates.^281^–^284^ We identified no studies of suicide risk following HIV diagnosis in the HAART era. Most recently, a large prospective cohort study of military applicants through 1993 found that suicide rates following routine screening was similar among 4,147 HIV-positive (49 per 100,000 person-years) and 12,437 HIV-negative (36 per 100,000 person-years), though marginally higher than in the general U.S. population.^285^ Several clinical trials from the HAART^286^–^288^ and the pre-HAART^289^–^292^ eras found that more intensive counseling was effective in reducing distress after notification of a positive test.

HIV-positive disclosure may increase rates of intimate partner or other violence.^293^ A study of 2,864 HIV-infected adults found that 12.6% reported relationship violence since diagnosis, with women reporting twice as much violence as men, and nearly half reporting HIV-positive seropositive status as a cause.^294^ Another study found that 4% of HIV-infected women reported violence after disclosure of status and 45% reported emotional, physical, or sexual abuse at some time after their diagnosis.^295^ A longitudinal study found that 68% (34 of 50) of HIV-positive women had evidence of physical or sexual abuse when initiating primary care for their infection, which was associated with increased illness and health care utilization over the next two years.^296^ HIV-negative and HIV-positive persons may have comparable rates of intimate partner violence, however, when matched on high-risk behaviors such as drug use.^297^–^299^ One prospective cohort study of newly diagnosed HIV infected persons found that rates of physical violence and emotional abuse declined rather than increased 6 months after partner notification of HIV status.^300^

A positive diagnosis could have other negative effects on close relationships, including partnership dissolution. One observational study, however, found that disclosure by seropositive men to their main male sex partner was associated with a relationship “as strong as ever” after 6 months in 80%, compared to 70% in seronegative men.^301^ Other studies have found that the rate of partnership dissolution after partner notification was similar to control groups of high-risk persons without HIV or relationships in which the partner was not notified.^300,^ ^302^

### Acceptability of screening

Because of the potentially serious consequences of HIV testing, there is general consensus that it should be voluntary and performed after obtaining informed consent.^126^ In the U.S., approximately half (43.5%%) of persons aged 18 to 64 years had been tested at least once for HIV.^303^ The proportion of adolescents tested for HIV infection is substantially lower. In 1995, for example, the proportion of women aged 15–19 years old who had ever been tested for HIV infection was 28%.^304^ Among persons reporting ongoing high-risk behaviors, recent studies indicate that 20%–30% had never been tested for HIV, and 27% to 67% had been tested in the previous year.^207,^ ^305,^ ^306^

We identified one good-quality systematic review of 62 studies on the acceptability of voluntary routine HIV antibody testing in the U.S.^307^ It found marked heterogeneity between studies with regard to design, measurement of predictor and outcome variables, statistical methods, and populations. Acceptance rates varied widely even within similar settings, such as family planning clinics (14% to 67%), gynecology patients (10% to 97%), STD clinic clients (29% to 92%), injection drug users (38% to 85%), hospital patients (11% to 91%), and prison inmates (47% to 89%). In general, low prevalence settings appeared to be associated with lower acceptance rates. Factors associated with higher acceptance rates included the client's perception of HIV risk, acknowledgment of risk behaviors, confidentiality protections, and the provider's belief that counseling and testing would be beneficial. In one study, women's fear of partner violence did not affect their decision to be tested.^308^

Guidelines for HIV testing recommend fairly extensive pre-test counseling.^126^ Effects of streamlined counseling or counseling targeted at specific groups such as minorities or adolescents to improve uptake rates have not been studied well, though a social marketing campaign in New York City to promote HIV testing among adolescents approximately doubled the number of HIV tests compared to the weeks before or after the campaign.^309^ Normalizing HIV testing by implementing ‘opt-out’ testing policies (notifying people that an HIV test is routine and performing it unless refused) could increase acceptance, but has mostly been evaluated in pregnant women.^310,^ ^311^ We identified one study from a low-prevalence STD clinic in the U.K. that found that testing rates increased from 35% to 65% after implementing opt-out testing, though no new cases were identified.^312^

One group not evaluated in the systematic review^307^ was sex partners of newly diagnosed HIV-infected persons. We identified six U.S. studies that reported the number of partners identified, notified, and tested through partner counseling and referral services.^235,^ ^313^–^317^ In these studies, 44%^317^ to 89%^235^ of identified partners were located and notified of their potential HIV exposure. Of these, the rate of testing ranged from 43%^313^ to 97%.^315^

Concerns about maintaining confidentiality could deter some patients from accepting HIV testing that is not performed anonymously.^318^–^320^ Observational studies from several states found that the introduction of anonymous testing was associated with increased testing rates.^321^–^323^ In Oregon, for example, overall rates of testing increased by 50% and the number of HIV-positive patients identified doubled compared to an earlier period when only confidential testing was offered.^322^ A multistate retrospective cohort study of 835 patients diagnosed with HIV found that anonymous testing was associated with higher initial mean CD4 count (427 vs. 267 cells/mm3).^324^ Other studies, however, have not clearly shown that availability of anonymous testing is associated with increased testing rates,^325,^ ^326^ or found that the elimination of anonymous testing resulted in only a transient decline in testing rates.^327^ In one study, few high-risk persons reported being deterred from testing because of concerns about name-based reporting,^328^ and in two others anonymous and confidential testing were associated with similar numbers of partners notified.^329,^ ^330^ In Connecticut, HIV testing rates doubled among 13 to 17 year old persons after removing a requirement for parental consent.^319^

Most studies assessing testing method preferences indicate that home sample collection kits, telephone-based counseling, rapid tests, on-site testing, or non-invasive tests are preferred to standard office-based blood testing.^331^–^340^ Potential barriers to acceptance of newer technologies include concerns about cost, privacy and reliability of the newer tests.^331,^ ^334,^ ^336,^ ^341^ We identified no clinical trials evaluating the incremental acceptability of newer screening technologies versus standard HIV antibody testing. One observational study set in an emergency department found that approximately 50% of patients accepted either standard or rapid testing,^342^ and another study set in a substance abuse treatment setting found that 100% of 150 patients accepting testing chose an oral fluid test over a standard blood test.^340^ Another recent study found that 29% to 69% of patients accepted routinely offered rapid testing in different settings.^343^ In studies of patients who accepted home sample collection^344,^ ^345^ or oral fluid tests,^346^ a substantial proportion (22% to 33%, and 58%, respectively) had not been previously tested. The use of newer technologies has not been shown to increase high-risk behaviors (home based sample collection)^265^ or rates of new sexually transmitted diseases (rapid tests).^347^

## Key Question 5. How Many Newly Diagnosed HIV-Positive Patients Meet Criteria for Antiretroviral Treatment or Prophylaxis for Opportunistic Infections? How Many Patients Who Meet Criteria for Interventions Receive Them?

### Proportion of newly diagnosed patients qualifying for interventions

In asymptomatic HIV-positive patients, viral load and CD4 count testing are used to determine eligibility for HAART and opportunistic infection prophylaxis.^14^ We identified no studies reporting both CD4 count and viral load in newly diagnosed patients. Seven U.S. studies in different settings found that among newly diagnosed persons, the proportion of patients with CD4 counts less than 200 cells/mm3 at diagnosis or when initial presenting for care ranged from 12% to 43%, and the proportion with CD4 counts less than 500 cells/mm3 ranged from 46% to 80%.^212,^ ^226,^ ^348^–^352^ Only two studies reported the proportion with CD4 counts less than 350 cells/mm3 (57%^352^ and 62%^212^). There has not been a consistent trend towards either earlier or later diagnosis over time.^348,^ ^353^–^356^

Screening could reduce the proportion of HIV-infected patients requiring HAART or prophylaxis for opportunistic infections by identifying persons at earlier stages of disease, before their CD4 counts have dropped below thresholds for interventions. In addition, patients who have an adequate CD4 count response to HAART can safely discontinue^17^ prophylaxis for PCP,^357^–^367^ toxoplasmosis,^363,^ ^368^ and MAC.^357,^ ^369^–^371^ We identified no studies estimating the effects of screening or treatment on the proportion of patients qualifying for different interventions. One European study found that the rate of discontinuation of PCP prophylaxis for any reason increased from 7.8 to 21.9 per 100 person-years between 1997 and 1998 in patients on HAART.^361^

### Proportion of patients receiving intervention

HIV-positive patients who qualify for interventions may not receive them. A significant proportion of patients do not return to receive the results of their HIV test or are unaware of their positive status for other reasons. Studies of HIV-infected injection drug users, for example, found that 7% to 47% incorrectly self-reported a negative status.^372^ In a large study of publicly funded testing sites across the U.S., 44% of all tested patients and 38% of those with a positive test results did not have a post-test counseling session.^373^ Another large study of high-risk persons found that 10% to 27% self-reported at least one failure to return for test results,^374^ and a large study of publicly funded testing sites in the state of California found that 16% failed to return.^375^ Two smaller studies of STD clinic patients found that despite low initial return rates, 79% to 93% of positive patients were eventually successfully located.^218,^ ^376^ Recent studies from Massachusetts^225^ and Georgia^226^ found that 82% (49 of 60) and 74% (55 of 74) of HIV-positive persons identified after the implementation of routine voluntary testing programs in urgent care centers learned their results. Clinic setting, demographic characteristics, and transmission risk group have been identified as predictors of failure to return in some studies.^374^–^377^ In one study, return rates were similar in patients receiving anonymous and confidential testing.^329^ We identified no studies evaluating the effects of different pre-test counseling methods on return rates.

The proportion of patients learning their test result could be affected by the use of newer test methods or other factors. Rapid testing was associated with a higher rate of HIV-positive persons learning their serostatus than standard testing in an anonymous testing clinic (100% vs. 86%),^378^ STD clinic (97% vs. 79%),^378^ and emergency room setting (73% vs. 62%).^342^ In two non-comparative studies, rapid testing resulted in >98% of patients learning their serostatus.^343,^ ^379^ A study of 174,316 persons who submitted home samples found that 95–96% called for results.^344^

HIV-positive patients may delay entry into medical care or not receive care at all. In 1996, an estimated 36% to 63% of patients with known or unknown HIV infection were seeing a provider outside an emergency room at least once every 6 months.^12^ U.S. studies have found that 17% to 29% of those in care had delayed entry into care for at least 3 months,^380,^ ^381^ and 11% to 39% delayed care for at least 1 year.^330,^ ^355,^ ^381^ A recent study found that 35% (26 of 74) HIV-infected persons identified through a routine voluntary screening program in an urgent care center had entered care within 4 months.^226^ A study of rapid testing found that entry into care within 6 months ranged from 100% (STD clinic) to 22% (jail).^343^ Delayed entry into care was associated with failure to receive post-test counseling in one study.^382^ Name-based surveillance did not appear to increase the rate of delayed care compared to anonymous testing.^330^

Patients diagnosed with infection may decline interventions, stop treatment, or not be offered therapy. We identified no studies that prospectively followed newly diagnosed HIV patients eligible for HAART and measured what proportion received appropriate treatment. Four large (n=1,411 to 9,530) U.S. surveys found that 53% to 85% of HIV-infected patients were receiving antiretroviral therapy according to then-current guidelines.^383^–^386^ In the largest, 57% of eligible patients were receiving HAART and 79% any antiretroviral therapy regimen.^386^ A similar range has been reported in smaller U.S. observational studies.^387^–^392^ In small studies of HIV-infected women and young (aged 14–29) persons, 23% to 35% had discontinued treatment and about 15% had not been offered it.^387,^ ^391^ Predictors of non-use of HAART varied between studies, but may include ongoing drug use,^385,^ ^386,^ ^390,^ ^392^–^394^ female gender,^384,^ ^386^ poor mental health, ^395^ minority status,^384,^ ^396^ lower education level,^384,^ ^388^ younger age,^383,^ ^388,^ ^389,^ ^393,^ ^394^ alcoholism^386^ or poorer access to care.^384,^ ^397^ In a 1997 study of U.S. HIV-infected patients, 93% appropriately received PCP prophylaxis, 62% MAC prophylaxis, and 73% toxoplasmosis prophylaxis.^398^ A recent study of 618 HIV-infected patients found that only one-quarter discussed ways to prevent transmission in that day's primary care visit.^399^

### Late testers

A significant proportion of patients with HIV infection are identified shortly before being diagnosed with AIDS, or concurrently with their AIDS diagnosis, and are often referred to as late testers. We identified no studies estimating the effects of screening on the proportion of late testers. In the U.S., the proportion of persons simultaneously diagnosed with HIV and AIDS was 26% to 27% in two large epidemiologic studies.^400,^ ^401^ Three studies found that among patients with newly diagnosed HIV infection, 37% to 43% were diagnosed with AIDS within one year.^402^–^404^ Conversely, two other studies found that the proportion of persons with AIDS who were diagnosed within one year of initial HIV diagnosis was 39% to 45%.^19,^ ^405^ Studies from Europe and Australia and pre-HAART era U.S. studies reported similar rates of late diagnosis.^406^–^413^

Antiretroviral interventions appear to be less effective in those who present with advanced immune deficiency, but some benefit is seen even with very low CD4 counts.^414^–^418^ We identified no studies estimating long-term (more than 3 years) effects of late diagnosis in patients who receive appropriate treatment. A large (n=12,574) collaborative analysis of 13 cohort studies from Europe and North America found that in treatment-naïve patients, the CD4 cell count at time of initiation of HAART was the dominant prognostic factor for three-year rates of AIDS or death (adjusted hazard ratio 0.18 [0.14–0.22] for CD4 cell count >350 cells/mm3 vs. <50 cells/mm3), with viral load a significant negative prognostic factor only when >100,000 copies/ml.^88^

## Key Question 6. What are the Harms Associated with the Work-Up for HIV Infection?

Checking viral loads or CD4 counts could increase anxiety levels^419^ or result in labeling, affect close relationships, or increase risky behaviors if patients feel that they are at low risk of infecting others. We identified no studies estimating the harms of measuring viral loads or CD4 counts in patients with chronic HIV infection.

## Key Question 7a. How Effective are Interventions (Antiretroviral Treatment, Counseling on Risky Behaviors, Immunizations, Routine Monitoring and Follow-Up, More Frequent Papanicolaou Testing, or Prophylaxis for Opportunistic Infections) in Improving Clinical Outcomes (Mortality, Functional Status, Quality of Life, Symptoms, Opportunistic Infections, or Transmission Rates)?

### Antiretroviral treatment

Clinical progression and mortality. HAART regimens with three or more antiretroviral agents used in combination are the current standard of care for HIV-infected persons receiving antiretroviral therapy.^14,^ ^15^ The use of agents from different classes is thought to be important in limiting the development of resistance.^27^ Recommended initial combinations usually consist of two nucleoside reverse transcriptase inhibitors (NRTI's) plus one protease inhibitor (PI) (or two protease inhibitors used in lower ‘boosting’ doses) or one non-nucleoside reverse transcriptase inhibitor (NNRTI).^14^ In early 2004, there were eight NRTI's, three NNRTI's, and eight PI's available in the U.S. If current guidelines for preferred initial antiretroviral therapy are followed, there are approximately 500 potential HAART combinations available.^14,^ ^15,^ ^420^ In contrast to regimens of one or two antiretroviral drugs that had waning effectiveness over time, ^421,^ ^422^ HAART regimens have been shown to result in durable suppression of viremia and sustained CD4 count increases for up to six years,^423^–^426^ though no treatment is able to completely eradicate latent HIV in cellular reservoirs.^33,^ ^427^–^429^

We identified one recent, good-quality systematic review of 54 randomized controlled trials of 16,684 HIV-infected patients with limited or no antiretroviral experience that found that that three-drug therapy was more effective than two-drug therapy (odds ratio 0.62 [95% CI, 0.50–0.78]).^421^ Another good-quality systematic review (14 trials) of mostly antiretroviral-experienced patients reported similar results.^430^ Although the systematic reviews found no studies evaluating true (non-boosted) four-drug versus three-drug regimens, recent randomized trials^431^–^435^ and a large collaborative analysis^436^ of thirteen prospective cohort studies found no significant differences in clinical outcomes between regimens with four versus three drugs. Several good-quality systematic reviews found two-drug superior to one-drug therapy (Table 4).^421,^ ^437^–^439^ Although no trials directly compared three-drug regimens to placebo, we indirectly calculated a relative risk of 0.35 for clinical progression or death (95% CI, 0.25, 0.47) using individual trial data reported in a good-quality recent systematic review (Appendix 5).^421^

Table 4 Effectiveness of Antiretroviral Regimens Using Different Numbers of Drugs

Regimen comparison | Relative risk for progression or death | Source | Type of study
Monotherapy vs. placebo or no therapy | 0.70 (0.60–0.80) | Jordan, 2002^421^ | Systematic review of 15 randomized trials
Dual therapy vs. monotherapy | 0.60 (0.51–0.70) | Jordan, 2002^421^ | Systematic review of 16 randomized trials
| 0.74 (0.67–0.82) for AZT + ddI vs. AZT alone | Darbyshire, 2003^438^ | Systematic review of 6 randomized trials AZT + ddI or AZT + ddC versus AZT alone; also briefly reviewed 5 trials of AZT + 3TC vs. AZT alone
| 0.86 (0.77–0.96) for AZT + ddC vs. AZT alone
| 0.35 (0.24–0.53) for AZT + 3TC vs. AZT alone
| 0.80 (0.72–0.89) for death | HIV Trialists' Collaborative Group, 1999^437^ | Systematic review of 6 randomized trials of AZT + ddI or AZT + ddC versus AZT alone
| 0.80 (0.74–0.87) for disease progression
| 0.51 (0.36–0.71) | Staszewski, 1997^439^ | Meta-analysis of 4 randomized trials of AZT + 3TC vs. AZT alone
Triple therapy vs. dual therapy | 0.65 (0.52–0.81) | Yazdanpanah, 2004^430^ | Systematic review of 14 randomized trials
| 0.62 (0.50–0.78) | Jordan, 2002^421^ | Systematic review of 9 randomized trials
Quadruple therapy vs. triple therapy | No significant differences | van Leth, 2004^431^ | Randomized controlled trials
| | Gerstoft, 2003^433^
| | Gulick, 2004^435^
| | Shafer, 2003^434^
| No significant differences | Chene, 2003^436^ | Collaborative analysis of 13 prospective cohort studies

AZT=zidovudine, ddI=didanosine, ddc=zalcitabine, 3TC=lamivudine

Numerous large U.S.^16,^ ^403,^ ^440,^ ^441^ and European^442^–^447^ cohort studies parallel the findings of the systematic reviews regarding the superiority of HAART. In addition, numerous observational studies from the U.S.,^16,^ ^440,^ ^441,^ ^448^–^453^ Europe,^442^–^444,^ ^454^–^460^ Canada,^461,^ ^462^ and Australia^463,^ ^464^ found a marked decline in the incidence of opportunistic illnesses and deaths in HIV-infected patients which coincided with the time period (1995-1997) that HAART became widely adopted. In two U.S. cohorts, for example, mortality rates declined from 20.2^441^ and 29.4^440^ per 100 person-years to 8.4 and 8.8 per 100 person-years, respectively. Recent European data indicate that the initial drop in mortality and morbidity after the introduction of HAART has been sustained through 2002.^465^

We identified 34 good or fair-quality (usually open-label) randomized trials that compared clinical outcomes from different HAART regimens in antiretroviral-naïve patients (Table 5, Evidence Table 1).^431^–^435,^ ^466^–^494^ Most trials ranged in duration from 24–52 weeks, with the longest^472^ three years. In each trial, the number of clinical events was too low to determine whether any specific regimen or regimen type (for example, PI-based versus NNRTI-based or triple NRTI) was superior for clinical outcomes. The three trials of longest duration, for example, reported overall rates of clinical progression of 2.1 per 100 person-years of follow-up after 2.3 years^434,^ ^484^ 1.3% (4/298) death or progression to CDC stage C after 2 years,^493^ and 5.2% (31/600) death or progression to CDC stage C after 3 years.^472^

Table 5 Head-to-Head Trials of Highly Active Antiretroviral Regimens in Treatment-Naive or Minimally Experienced HIV-1 Infected Patients

Author, year | Study duration and number enrolled | Interventions | HIV-1 viral load or other virologic outcomes | CD4 count increase (cells/mm^3^) | Clinical outcomes | Withdrawal due to adverse events | Internal validity rating
2 NRTI + 1 NNRTI versus 2 NRTI + 1 PI
Maggiolo,* 2003^477^ | 52 weeks | A: ddI + 3TC + EFV (once daily regimen) | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | FAIR
| 102 | B: AZT + 3TC + EFV | <50 copies/ml at 52 weeks: 77.4% vs. 77.4% vs. 50% (p=0.02) | Mean 194 vs. 183 vs. 165 | Death: None reported | 9% vs. 12% vs. 26% | Open-label
| | C: AZT + 3TC + NFV | | | Disease progression: 0/34 vs. 1/34 vs. 1/34
Podzamczer, 2002^483^ | 12 months | A: AZT/3TC + NFV | A vs. B | A vs. B | A vs. B | A vs. B | FAIR
Combine Study | 142 | B: AZT/3TC + NVP | <20 copies/ml at 12 months: 50% vs. 65% (p=0.06) | Mean 173 vs. 162 (p=0.01) | Deaths: None | 21% vs. 25% (p>0.2) | Open-label
| | | | | AIDS-defining disease: 0/70 vs. 1/72
Squires, 2004^489^ | 48 weeks | A: AZT/3TC + atazanavir | A vs. B | A vs. B | A vs. B | A vs. B | GOOD
| 810 | B: AZT/3TC + EFV | <50 copies/ml at 48 weeks: 32% vs. 37% (NS) | Median 455 vs. 446 | Deaths: 2/401 (0.5%) vs. 3/404 (0.7%) | 6% vs. 8%
| | | | | CDC stage C:4/401 (1.0%) vs. 4/404 (1.0%)
Staszewski, 1999^491^ | Median 48 weeks | A: AZT + 3TC + EFV | A vs. B | A vs. B | A vs. B | A vs. B | FAIR
Study 006 | 450 | B: AZT + 3TC + IDV | <50 copies/ml at 48 weeks: 64% vs. 43% (p<0.05) | Mean 201 vs. 185 | Number of new AIDS-defining illnesses: 7/154 vs. 9/148 (NS) | 6% vs. 20% (p<0.001) | Open-label
| | C: EFV + IDV (results not reported here)
van Leeuwen,* 2003^493^ | 96 weeks | A: d4T + ddI + IDV | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | FAIR
Atlantic | 298 | B: d4T + ddI + NVP | <50 copies/ml at 48 weks: 55% vs. 54% vs. 46% (p=0.353) | Mean increase 238 vs. 139 vs. 233 (p=0.13) | Death: 0% vs. 0% vs. 1/109 (1%) | 12% vs. 7% vs. 9% | Open-label
| | C: d4T + ddI + 3TC | <50 copies/ml at 96 weeks: 44% vs. 55% vs. 28% (p<0.001) | | Progression to CDC stage C: 1/100 (1%) vs. 1/89 (1%) vs. 1/109 (1%)
2 NRTI + 1 PI vs. 2 NRTI + 1 PI
Carr, 2000^466^ | 52 weeks | A: AZT + 3TC + IDV | A vs. B vs. C | A vs. B vs. C | Quality of life improved in all groups, no differences between interventions, using unspecified scale | A vs. B vs. C | FAIR
OzCombo1 | 106 | B: d4T + 3TC + IDV | <50 copies/ml at 52 weeks: 66% vs. 59% vs. 48% | Mean 275 vs. 237 vs. 176 | | 23% vs. 12% vs. 24% | Open-label
| | C: d4T + ddI + IDV
Cohen Stuart, 1999^467^ | 24 weeks | A: AZT + 3TC + IDV | A vs. B | A vs. B | A vs. B | A vs. B | FAIR
CHEESE | 70 | B: AZT + 3TC + SQV-soft gel capsule | <50 copies/ml at 24 weeks: 74% vs. 71% (p=0.78) | Mean 162 vs. 89 (p=0.01) | Death: 1/35 vs. 2/35 | 3% vs. 11% | Open-label
| | | | | New AIDS-defining events: 3/35 vs. 5/35 (NS)
Eron, 2004^468^ | 48 weeks | A: d4T 40 mg bid + 3TC 150 mg bid + lopinavir 800 mg/RTV 200 mg qD | A vs. B | A vs. B | No deaths or CDC stage C events | A vs. B | FAIR
| 38 | B: d4T 40 mg bid + 3TC 150 mg bid + lopinavir 400 mg/RTV 100 mg bid | <50 copies/ml at week 48: 14/19 (74%) vs. 15/19 (79%) (p=0.70) | Mean 235 vs. 248 | | 5% vs. 5% | Open-label
Eron, 2000^469^ | 48 weeks | A: d4T + ddI + IDV | A vs. B | A vs. B | A vs. B | A vs. B | FAIR
START II | 205 | B: AZT + 3TC + IDV | <50 copies/ml at 48 weeks: 41% vs. 35% (p>0.2) | Median 214 vs. 142 (p=0.026) | Death: 2/102 (2%) vs. 0/103 (0%) | 16% vs. 16% | Open-label
| | | | | New CDC class C
| | | | | AIDS defining event: 1/102 (1%) vs. 1/103 (1%)
Gathe,2004^475^ | 48 weeks | A: abacavir + 3TC + fosamprenavir | A vs. B | A vs. B | No deaths or clinical progression reported | A vs. B | FAIR
| 649 | B: abacavir + 3TC + NFV | <50 copies/ml at 48 weeks: 56% vs. 52% (NS) | Median 203 vs. 207 | | 8% vs. 5% | Open-label
Gathe, 2002^474^ | 48 weeks | A: Enteric-coated ddI + d4T + NFV | A vs. B | A vs. B | A vs. B | Not reported | FAIR
| 511 | B: AZT + 3TC + NFV | <50 copies/ml at 48 weeks: 32% overall, no difference between groups | Mean 157 vs. 189 (NS) | Deaths: 3 vs. 2 (sample sizes not clear) | | Number in each arm not reported
| | | | | AIDS-defining diseases: None reported
Kirk,* 1999^432^ | 24 weeks | A: AZT + 3TC + IDV | A vs. B vs. C (antiretroviral naïve patients only) | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C (all patients) 8.3% vs. 36.8% vs. 16.1% (p<0.001) | FAIR
Danish Protease Inhibitor Study | 119 antiretroviral naïve | B: AZT + 3TC + RTV | <=20 copies/ml at 24 weeks: 37.5% vs. 20.8% vs. 56.4%, (p<0.01 for C vs. A or B) | Median 132 vs. 117 vs. 110 (p=0.82) | Deaths: 4/284 overall, no significant differences | | Open-label
| | C: AZT + 3TC + RTV + SQV | | | New or recurrent AIDS-defining events: 16/284 overall, no significant differences
Murphy, 2003^481^ | 48 weeks | A: Atazanavir 400 mg qD + 3TC 150 mg bid + d4T 40 mg bid | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | FAIR.
Study AI424-008 | 467 enrolled | B: Atazanavir 600 mg qD + 3TC 150 mg bid + d4T 40 mg bid | <50 copies/ml at week 48: 35% (63/181) vs. 36% (71/195) vs. 34% (31/91) (NS) | Mean 234 vs. 243 vs. 211 (NS) | Deaths: 1/181 (0.5%) vs. 2/195 (1%) vs. 0/91 (0%) | 5% vs. 7% vs. 4% | Blinded only to atazanavir dose
| | C: NFV 1250 mg bid + 3TC 150 mg bid + d4T 40 mg bid | | | Clinical progression: None reported
Murphy, 2001^480^ | 48 weeks | Group I | A vs. B | A vs. B | Death: None reported | 0% | GOOD
| 32 enrolled in group I | A: d4T + 3TC + lopinavir 200 mg/RTV 100 mg bid | <50 copies/ml at 48 weeks: 100% (16/16) vs. 50% (8/16) (p=0.002) | Mean 244, no significant differences | New AIDS-defining events: One (group not reported)
| 68 enrolled in group II | B: d4T + 3TC + lopinavir 400 mg/RTV 100 mg bid | C vs. D | C or D
| | Group II | <50 copies/ml at 48 weeks: 86% vs. 73% (NS) | Mean 213, no significant differences
| | C: d4T + 3TC + lopinavir 400/RTV 100 mg bid
| | D: d4T + 3TC + lopinavir 400/RTV 200 mg bid
Rodriguez-French, 2004^485^ | 48 weeks | A: 3TC + abacavir + fosamprenavir | A vs. B | A vs. B | No deaths reported | A vs. B | FAIR
NEAT | 251 | B: 3TC + abacavir + NFV | <50 copies/ml at 48 weeks: 58% vs. 42% (95% CI for difference 3–28%) | Median 201 vs. 216 | No AIDS-defining events reported | 5% vs. 6% | Open-label
Saag, 2001^487^ | 24 weeks initial intervention, | A: AZT + 3TC + NFV 750 tid | A vs. B | A vs. B | A vs. B | 2–4% overall | GOOD
Agouron study 511 | 24 weeks extension | B: AZT + 3TC + NFV 500 mg tid | <50 copies/ml at 24 weeks: 55% vs. 30% (p<0.001) | Mean at week 24: 148 vs. 135 (estimated from graph) | Death: None reported
| 316 | C: AZT + 3TC (results of this arm not reported here) | <50 copies/ml at 48 weeks (extension phase): 45% vs. 27% (p=0.008) | Mean at week 48: 190 vs. 188 (estimated from graph) | New AIDS-defining events: None reported
Sanne, 2003^488^ | 48 weeks | A: ddI + d4T + atazanavir 200 mg qD | A vs. B vs. C vs. D | A vs. B vs. C vs. D | A vs. B vs. C vs. D | A vs. B vs. C vs. D | GOOD
Protocol 007 | 420 | B: ddI + d4T + atazanavir 400 mg qD | <50 copies/ml at 48 weeks: 28% vs. 36% vs. 42% vs. 39% (NS) | Mean 220 vs. 221 vs. 208 vs. 185 | Death: 2/83 vs. 0/78 vs. 2/79 vs. 1/82 | Withdrawal (adverse events): 5% vs. 6% vs. 9% vs. 7% | Blinded to atazanavir dose
| | C: ddI + d4T + atazanavir 500 mg qD
| | D: ddI + d4T + NFV
Squires, 2000^490^ | 48 weeks | A: d4T + 3TC +IDV | A vs. B | A vs. B | A vs. B | A vs. B | FAIR
START I | 204 | B: AZT + 3TC + IDV | <50 copies/ml at 48 weeks: 49% vs. 47% (p=0.834) | Median 227 vs. 198 (p=0.385) | Death: 0/101 (0%) vs. 1/103 (1%) | 5% vs. 6% | Open-label
| | | | | Disease progression: 0/101 (0%) vs. 1/103 (1%)
Walmsley, 2002^494^ | 48 weeks | A: d4T + 3TC + lopinavir/RTV | A vs. B vs. C | A vs. B | A vs. B | A vs. B | GOOD
M98–863 | 686 | B: d4T + 3TC + NFV | <50 copies/ml at 48 weeks: 67% vs. 52% (p<0.001) | Mean 207 vs. 195 | Death: 5/326 (1.5%) vs. 3/327 (0.9%) | 3.4% vs. 3.7%
2 NRTI + 1 NNRTI vs. 2 NRTI + 1 NNRTI
French, 2002^471^ | 52 weeks | A: AZT + 3TC + NVP | A vs. B vs. C | A vs. B vs. C | No deaths | A vs. B vs. C | FAIR
Ozcombo 2 | 70 | B: d4T + ddI + NVP | <50 copies/ml at 52 weeks: 73% vs. 68% vs. 80% | Mean 139 vs. 113 vs. 174 | No clinical progression | 15% vs. 18% vs. 13% | Open-label
| | C: d4T + 3TC + NVP
Gallant, 2004^472^ | 144 weeks | A: Tenofovir DF + 3TC + EFV | A vs. B | A vs. B | A vs. B | A vs. B | GOOD
903 Study | 602 | B: d4T + 3TC + EFC | <50 copies/ml at 144 weeks: 68% vs. 62% | Mean 263 vs. 283 | Death: 5/299 (2%) vs. 6/301 (2%) | 8% vs. 14%
| | | | | Category C AIDS-defining conditions: 11/299 vs. 9/301 (p=0.40)
Garcia, 2000^473^ | 12 months | A: d4T + ddI 150–200 mg bid + NVP 200 mg bid | A vs. B | A vs. B | No deaths | A vs. B | FAIR
Spanish Scan Study | 94 | B: d4T + ddI 300–400 mg qD + NVP 400 mg qD | <5 copies/ml at 12 months: 40% vs. 45% (NS) | Mean 132 vs. 154 (p=0.7) | No AIDS-related clinical events | 7% vs. 9% | Open-label
Nunez, 2002^482^ | 48 weeks | A: d4T + ddI + NVP | A vs. B | A vs. B | A vs. B | A vs. B | FAIR
SENC | 67 | B: d4T + ddI + EFV | <50 copies/ml at 48 weeks: 64% vs. 74% (p=0.43) | Mean 119 vs. 117 | Deaths: None reported | 8.3% vs. 13% | Open-label
| | | | | AIDS-defining diseases: None reported
Saag,* 2004^486^ | 60 weeks | A: Emtricitabine + ddI + EFV | A vs. B | A vs. B | A vs. B | A vs. B | GOOD
FTC-301A | 580 | B: d4T + ddI + EFV | <50 copies at 60 weeks: 76% vs. 54% | Mean 168 vs. 134 | Death: 0 vs. 2/285 (0.7%) | 6.7% vs. 13%
| | | | | Clinical progresssion: 5/286 (1.7%) vs. 10/285 (3.5%)
van Leth,* 2004^431^ | 48 weeks | A: d4T + 3TC + NVP 400 mg qD | A vs. B vs. C vs. D | A vs. B vs. C vs. D | A vs. B vs. C vs. D | A vs. B vs. C vs. D | FAIR
2NN | 1216 | B: d4T + 3TC + NVP 200 mg bid | <50 copies/ml at 48 weeks: 70.0% vs. 65.4% vs. 70.0% vs. 62.7% (p=0.193) | Median 170 vs. 160 vs. 160 vs. 150 (p=0.8) | Death: 7/220 (3.2%) vs. 9/387 (2.3%) vs. 7/400 (1.8%) vs. 2/209 (1.0%) | Temporary or premanent discontinuation of study drug due to adverse or HIV event: 24% vs. 22% vs. 16% vs. 30% | Open-label
| | C: d4T + 3TC + EFV 600 mg qD | Treatment failure (virologic, clinical progression, or therapy change) by week 48: 96/220 (44%) vs. 169/387 (44%) vs. 151/400 (38%) vs. 111/209 (53%) | | Clinical progression: 7/220 (3.2%) vs. 11/387 (2.8%) vs. 10/400 (2.5%) vs. 5/209 (2.4%)
| | D: d4T + 3TC + NVP 400 mg qD + EFV 800 mg qD
3 NRTI vs. other regimens
Gerstoft,* 2003^433^ | 48 weeks | A: d4T + ddI + abacavir | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | FAIR
| 182 | B: AZT + 3TC + RTV + SQV | <20 copies/ml at 48 weeks: 43% vs. 62% vs. 69% (p<0.01 for A vs. C and p<0.05 for A vs. B) | Median 140 vs. 140 vs. 185 (NS) | Deaths: 2/60 vs. 1/60 vs. 2/50 | Severe (grade 4) adverse events, including hospitalizations: 13% vs. 7% vs. 12% (NS) | Open-label, protocol modified after enrollment already started
| | C: AZT + 3TC + NFV + NVP | | | New AIDS defining event: 1/60 vs. 2/60 vs. 2/60
Gulick,* 2004^435^ | Study stopped after mean 32 weeks | A: AZT + 3TC + abacavir | A vs. B or C | A vs. B or C | Death: 7/1147 overall | A vs. B or C | GOOD
ACTG A5095 | 1147 | B: AZT + 3TC + EFV | <50 copies/ml at 48 weeks: 61% vs. 83% (p<0.05) | Mean 174 vs. 173 (p=0.58) | Clinical progression: Not reported | Withdrawal (overall): 7%, no significant differences between groups
| | C: AZT + 3TC + abacavir + EFV
Matheron, 2003^479^ | 48 weeks | A: AZT/3TC + abacavir | A vs B | A vs. B | A vs. B | A vs. B | FAIR
CNAF3007 | 195 | B: AZT/3TC + NFV | <50 copies/ml at 48 weeks: 57% vs. 58% (p=0.85) | Median 110 vs. 120 | Progression from CDC stage A to B: 2/77 vs. 1/76 | 16% vs. 16% | Open-label
| | | | | Progression from CDC stage B to C: 0/21 vs. 1/20
Staszewski, 2001^492^ | 48 weeks | A: 3TC + AZT + abacavir | A vs. B | A vs. B | A vs. B | A vs. B | GOOD
CNAAB3005 | 562 | B: 3TC + AZT + IDV | <50 copies/ml at 48 weeks: 40% vs. 46% (NS) | Median increase in CD4 count area under the curve: 107 vs. 93 (NS) | New AIDS-defining illness: 3/262 vs. 1/265 | 17% vs. 22%
| | | | | Deaths: 3/262 vs. 1/265
van Leeuwen,* 2003^493^ | 96 weeks | A: d4T + ddI + IDV | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | FAIR
Atlantic | 298 | B: d4T + ddI + NVP | <50 copies/ml at 48 weeks: 55% vs. 54% vs. 46% (p=0.353) | Mean increase 238 vs. 139 vs. 233 (p=0.13) | Death: 0% vs. 0% vs. 1/109 (1%) | 12% vs. 7% vs. 9% | Open-label
| | C: d4T + ddI + 3TC | <50 copies/ml at 96 weeks: 44% vs. 55% vs. 28% (p<0.001) | | Progression to CDC stage C: 1/100 (1%) vs. 1/89 (1%) vs. 1/109 (1%)
1 NRTI + 1 NNRTI + 1 PI vs. other regimens
Launay, 2002^476^ | 72 weeks | A: d4T + NVP 200 mg bid + IDV 1000 mg tid | A vs. B | A vs. B | A vs. B | A vs. B | FAIR
ANRS 081 | 145 | B: d4T + 3TC + IDV 800 mg tid (n=71) | <20 copies/ml at 72 weeks: 52% vs. 79% | Median 198 vs. 242 (p=0.08) | Deaths: None reported | 46% vs. 25% | Open-label
| | | | | AIDS-defining diseases: None reported
4 DRUG REGIMENS VS. 3 DRUG REGIMENS
Fischl, 2003^470^ | 2.1 years | A: AZT 300 mg/3TC 150 mg bid + IDV 800 tid | A vs. B vs. C | A vs. B vs. C | Overall Deaths: 13/517 (2.5%) | Withdrawal (adverse events): not reported | FAIR
ACTG 388 | 517 | B: AZT 300 mg/3TC 150 mg bid + IDV 1000 mg tid + EFV 600 mg qD | Virologic failure (increase in viral load greater than baseline or l.0 log greater than nadir, viral load >200 copies/ml at week 24, or virologic relapse): 31% vs. 23% vs. 46% (p=0.04 for B vs. A, p=0.06 for C vs. A) | Mean at week 96: 250 vs. 265 vs. 257 (NS) | AIDS-defining cases: 59/517 (11%); | Grade 3 or 4 adverse event: 35/168 (21%) vs. 41/173 (24%) vs. 50/175 (28%) (p=0.49 for A vs. B and p=0.12 for A vs. C) | Open-label
| | C: AZT 300 mg/3TC 150 mg bid + IDV 1000 bid + NFV 1250 bid | | | 5.7/100 person-years
| | | | | AIDS or death: 6.9/100 person-years
Gerstoft,* 2003^433^ | 48 weeks | A: d4T + ddI + abacavir | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | FAIR
| 182 | B: AZT + 3TC + RTV + SQV | <20 copies/ml at 48 weeks: 43% vs. 62% vs. 69% (p<0.01 for A vs. C and p<0.05 for A vs. B) | Median 140 vs. 140 vs. 185 (NS) | Deaths: 2/60 vs. 1/60 vs. 2/50 | Severe (grade 4) adverse events, including hospitalizations: 13% vs. 7% vs. 12% (NS) | Open-label, protocol modified after enrollment already started
| | C: AZT + 3TC + NFV + NVP | | | New AIDS defining event: 1/60 vs. 2/60 vs. 2/60
Gulick,* 2004^435^ | Study stopped after mean 32 weeks | A: AZT + 3TC + abacavir | A vs. B or C (B and C similar rates) | A vs. B or C | Death: 7/1147 overall | A vs. B or C | GOOD
ACTG A5095 | 1147 | B: AZT + 3TC + EFV | <50 copies/ml at 48 weeks: 61% vs. 83% (p<0.05) | Mean 174 vs. 173 (p=0.58) | Clinical progression: | Withdrawal (overall): 7%, no significant differences between groups
| | C: AZT + 3TC + abacavir + EFV | | | Not reported
Kirk,* 1999^432^ | 24 weeks | A: AZT + 3TC + IDV | A vs. B vs. C (antiretroviral naïve patients only) | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C (all patients) 8.3% vs. 36.8% vs. 16.1% (p<0.001) | FAIR
Danish Protease Inhibitor Study | 119 antiretroviral naïve | B: AZT + 3TC + ritonavir | <=20 copies/ml at 24 weeks: 37.5% vs. 20.8% vs. 56.4%, (p<0.01 for C vs. A or B) | Median 132 vs. 117 vs. 110 (p=0.82) | Deaths: 4/284 overall, no significant differences | | Open-label
| | C: AZT + 3TC + ritonavir + SQV | | | New or recurrent AIDS-defining events: 16/284 overall, no significant differences
Shafer, 2003^434^ | Mean 2.3 years | A: ddI + d4T + EFV followed by AZT + 3TC + NFV | Virologic failure of two sequential regimens or premature discontinuation: | Median 295 cells/cubic millimeter, no significant differences | A, B, C, or D vs. E or F | A vs. B vs. C vs. D vs. E vs. F | GOOD
| 987 | B: ddI + d4T + NFV followed by AZT + 3TC + EFV | A, B, C, or D (three-drug regimens) vs. E or F (four-drug regimens): 44% vs. 47% (NS) | | Death: 6/620 (1%) vs. 6/360 (2%) | 14% vs. 13% vs. 7% vs. 4% vs. 13% vs. 7% | Blinded to EFV and NFV but not to other antiretrovirals
| | C: AZT + 3TC + EFV followed by ddI + d4T + NFV | F vs. C | | AIDS-defining events: 4% overall, no significant differences
| | D: AZT + 3TC + NFV followed by ddI + d4T + EFV | <50 copies/ml at 24 weeks: 84% vs. 94%
| | E: ddI + d4T + EFV + NFV
| | F: AZT + 3TC + EFV + NFV
van Leth,* 2004^431^ | 48 weeks | A: d4T + 3TC + NVP 400 mg qD | A vs. B vs. C vs. D | A vs. B vs. C vs. D | A vs. B vs. C vs. D | A vs. B vs. C vs. D | FAIR
2NN | 1216 | B: d4T + 3TC + NVP 200 mg bid | <50 copies/ml at 48 weeks: 70.0% vs. 65.4% vs. 70.0% vs. 62.7% (p=0.193) | Median 170 vs. 160 vs. 160 vs. 150 (p=0.8) | Death: 7/220 (3.2%) vs. 9/387 (2.3%) vs. 7/400 (1.8%) vs. 2/209 (1.0%) | Temporary or premanent discontinuation of study drug due to adverse or HIV event: 24% vs. 22% vs. 16% vs. 30% | Open-label
| | C: d4T + 3TC + EFV 600 mg qD | Treatment failure (virologic, clinical progression, or therapy change) by week 48: 96/220 (44%) vs. 169/387 (44%) vs. 151/400 (38%) vs. 111/209 (53%) | | Clinical progression: 7/220 (3.2%) vs. 11/387 (2.8%) vs. 10/400 (2.5%) vs. 5/209 (2.4%)
| | D: d4T + 3TC + NVP 400 mg qD + EFV 800 mg qD
Other regimen comparisons (once-daily regimens, preplanned sequential regimens, scheduled alternation)
Maggiolo,* 2003^477^ | 52 weeks | A: ddI + 3TC + EFV (once-daily regimen) | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | A vs. B vs. C | FAIR
| 102 | B: AZT + 3TC + EFV | <50 copies/ml at 52 weeks: 77.4% vs. 77.4% vs. 50% (p=0.02) | Mean 194 vs. 183 vs. 165 | Death: None reported | 9% vs. 12% vs. 26% | Open-label
| | C: AZT + 3TC + NFV | | | Disease progression: 0/34 vs. 1/34 vs. 1/34
Martinez-Picado, 2003^478^ | 48 weeks | A: ddI + d4T + EFV | C vs. A or B | Mean 1.9/week in all groups, no significant differences | Deaths: None reported | A vs. B vs. C | FAIR
SWATCH | 161 | B: AZT + 3TC + NFV | <50 copies/ml at 48 weeks: 37/54 (67%) vs. 61/99 (58%) [odds ratio 1.2, CI 1.0 to 1.3] | | AIDS-defining illnesses: None reported | Treatment change due to adverse event: 10% vs. 14% vs. 17% (p>0.2 for A vs. B and for A or B vs. C) | Open-label
| | C: Scheduled alternation of A and B every 3 months | | | Quality of life score (5-point scale adapted from Medical Outcomes Study-HIV Questionnaire): 4.3 (A or B) vs. 4.5 (C) (NS)
Robbins, 2003^484^ | Mean 2.3 years | A: ddI + d4T + EFV followed by AZT + 3TC + NFV | Virologic failure of two sequential regimens or premature discontinuation: overall 272/620 (44%) | Median 285 at week 144, no significant differences | Deaths: 6/620 (1%) overall | See Shafer 2003 | GOOD
| 620 | B: ddI + d4T + NFV followed by AZT + 3TC + EFV | C vs. D: HR 0.71 (95% CI, 0.48, 1.06) | | AIDS-defining events: 20/620 (3%) overall, no significant differences | | Blinded to EFV and NFV but not to other antiretrovirals
| | C: AZT + 3TC + EFV followed by ddI + d4T + NFV | A vs. B: HR 1.29 (95% CI, 0.88, 1.89)
| | D: AZT + 3TC + NFV followed by ddI + d4T + EFV | C vs. A: HR 0.68 (95% CI, 0.46, 1.01)
| | | D vs. B: HR 1.22 (95% CI, 0.84, 1.79)
Saag,* 2004^486^ | 60 weeks | A: Emtricitabine + ddI + EFV (once-daily regimen) | A vs. B | A vs. B | A vs. B | A vs. B | GOOD
FTC-301A | 580 | B: d4T + ddI + EFV | <50 copies at 60 weeks: 76% vs. 54% | Mean 168 vs. 134 | Death: 0 vs. 2/285 (0.7%) | 6.7% vs. 13%
| | | | | Clinical progresssion: 5/286 (1.7%) vs. 10/285 (3.5%)

* Trial listed more than one time in table

Trials organized by type of regimen comparison (indicated by interventions highlighted in bold)

Quality of life and functional status. Few trials have adequately assessed the effect of HAART on quality of life or functional status (such as ability to work). A good-quality systematic review found that only two^495,^ ^496^ out of nine trials evaluating HAART regimens versus double therapy gave useful information regarding quality of life.^421^ In addition to these 2 fair-quality trials, we identified 2 other trials ^497,^ ^498^ of three- versus two-drug regimens and four trials^466,^ ^471,^ ^478,^ ^499^ of different HAART regimens that evaluated QOL outcomes. Two other clinical trials^500,^ ^501^ and one meta-analysis^502^ did not meet inclusion criteria.

All of the trials except three^466,^ ^471,^ ^497^ used the 35-item Medical Outcomes Study HIV Health Study (MOS-HIV), a validated HIV disease-specific measure of health-related quality of life.^503,^ ^504^ We identified no studies evaluating the effects of HAART regimens on the ability to work. Of the trials of three- versus two-drug regimens, two^496,^ ^498^ reported better QOL scores with the two-drug regimen and two^495,^ ^497^ with the three-drug regimen. In the four trials comparing different HAART regimens, no significant differences for QOL outcomes were seen.^466,^ ^471,^ ^478,^ ^499^ In all included trials, it was not clear if patients were blinded to markers of response to therapy before re-assessing quality of life.

Spread of disease. HAART could decrease the spread of HIV from infected persons by decreasing viral loads and shedding of HIV-1 in genital secretions.^51,^ ^52,^ ^505,^ ^506^ A 6-year longitudinal study of initially uninfected young homosexual men in San Francisco, for example, estimated that the per-partnership probability of HIV transmission from an infected partner decreased from 0.120 in 1994 to 0.048 in 1999 and paralleled the widespread adoption of HAART.^507^ On the other hand, increases in risky behaviors by patients on HAART could offset the beneficial effects of viral suppression.^508^ Another epidemiologic study from San Francisco, for example, found that although HAART use among men who have sex with men increased from 4% in 1995 to 54% in 1999, the proportion reporting high-risk sexual behaviors also increased (from 24% to 45%), and the annual HIV incidence increased from 2.1% in 1996 to 4.2% in 1999.^509^ In a large (11,516) U.S. retrospective study, the use of HAART by HIV-infected persons was associated with an increased likelihood (hazard ratio 4.10, 95% confidence interval 2.84–5.94) of developing an STD.^510^ Other studies have also observed increases in sexually transmitted diseases in persons with HIV infection^511^ and high-risk persons not known to be infected.^512^–^516^ In one large prospective cohort study, HAART use was associated with a higher risk for pregnancy (adjusted RR 1.3; 95% CI 1.0, 1.6) compared to other antiretroviral therapy regimens.^517^

Increased risky behaviors in HIV-infected persons could be related to optimism about the benefits of HAART, improvements in intermediate markers after treatment, or other factors.^518,^ ^519^ We identified one recent good-quality meta-analysis of 25 studies that evaluated whether being treated with HAART, having an undetectable viral load, or holding specific beliefs about HAART and viral load was associated with increased likelihood of engaging in unprotected sex.^520^ It found no association between HIV-infected persons being receipt of HAART or having an undetectable viral load and an increased likelihood of unprotected sex, but among seronegative and seropositive persons, unprotected intercourse was associated with optimistic beliefs about HAART or an undetectable viral load (OR 1.82, 95% CI, 1.52–2.17). Recent European studies^521,^ ^522^ reported similar findings, and a small (n=57) Dutch study^523^ also found that perceived (but not actual) favorable viral load was associated with increased risky behavior. A recent study of injection drug users on HAART found that improvements in CD4 count were associated with an increased risk of engaging in unprotected intercourse, though not with increased risky injection drug practices.^524^

We identified no cohort studies or clinical trials estimating the effects of HAART on horizontal transmission rates. One cohort study found that the rate of heterosexual transmission was lower from monogamous zidovudine-treated than untreated men (RR 0.5, 95% CI, 0.1 to 0.9).^525^ An epidemiologic study found that the annual HIV transmission rate from HIV-seropositive to HIV-seronegative persons in the U.S. dropped from 100% in 1979 to 18.4% in 1986, slowly declined from 13% in 1987 (the year that AZT was introduced) to 5.5% in 1989, and has remained steady at approximately 4.2% since 1990, with no decline around the time HAART was introduced.^526^ It was not designed to assess the relative contribution of antiretroviral therapy, changes in high-risk behaviors, or other factors to changes in transmission rates.

### Effects of counseling regarding risky behaviors on clinical outcomes (HIV transmission, sexually transmitted diseases)

A substantial proportion of HIV-infected persons report ongoing behaviors that increase the risk of transmitting the disease such as inconsistent condom use, multiple sexual partners, injection drug use, or trading sex for drugs or money.^381^ Managing high risk behavior remains an important goal for reducing HIV transmission.^527^–^529^ A client-centered approach, which includes personalized risk assessment and developing an individualized risk assessment plan, has been recommended by the CDC.^126,^ ^529^ Recently, the CDC has promoted the adoption of simplified counseling and testing procedures.^530^ Because testing and counseling for HIV occur in conjunction, it is difficult to separate their individual effects.

There is little evidence estimating the impact of testing and counseling on HIV transmission rates. We identified one prospective U.S. study of 144 serodiscordant heterosexual couples who received counseling and reported reduced risky behaviors that found no seroconversion after 193 couple years of follow-up.^531^ A prospective African study found that the rate of seroconversion among uninfected female partners of HIV-positive men was 6–9/100 person-years, compared to 22/100 person-years in women with untested partners.^532^

We identified three observational studies that evaluated the association between testing and counseling for HIV and subsequent rates of sexually transmitted diseases. Two studies found that HIV testing and counseling was associated with a moderate (about 33%) decrease in sexually transmitted diseases after HIV testing among those who tested positive, but increased the risk for those who tested negative (RR 1.27 to 2).^533,^ ^534^ One of these studies was performed in a young (aged 15–25), primarily Black population.^534^ The third study found that rates of sexually transmitted diseases following testing were similar for both HIV-positive (10%) and HIV-negative (9%) persons, but did not compare these to rates before testing.^535^

More intense HIV counseling could be more effective than standard counseling in reducing high-risk behaviors and sexually transmitted diseases or HIV infection rates, but would require additional resources. We identified one randomized controlled trial of 5758 heterosexual, HIV-negative persons that found that interactive HIV counseling and testing was associated with 20% fewer sexually transmitted diseases after twelve months than standard non-interactive didactic counseling and testing.^536^ There was no significant difference in the rate of new HIV infections (eight total). Another randomized controlled trial of 366 HIV-positive women also found that more intensive counseling was associated with fewer sexually transmitted diseases than standard counseling.^537^ A clinical trial of 399 heterosexual adults not known to be HIV-infected, on the other hand, found no differences in STD rates with more intense, multi-session cognitive behavioral counseling versus standard counseling, though it did find favorable effects on risky behaviors.^538^ We also identified one observational study that found that men newly diagnosed with HIV between 1991-1993, when counseling and early medical and social work interventions were offered, had a lower rate of gonorrhea (3.3%) compared to men diagnosed in 1988-1989 (8.3%), when early interventions were not offered.^539^ Temporal trends in sexual behaviors and HIV management not associated with more intense counseling and early intervention may have affected the results of this study.

We identified no studies estimating the effects of testing and counseling HIV-positive persons regarding injection drug use behaviors on transmission rates.

### Immunizations

Pneumococcal vaccination is recommended in all patients with HIV infection.^17^ Bacterial pneumonia is more frequent in HIV-positive persons, particularly at CD4 counts below 200 cells/mm3,^540^–^542^ though the use of HAART is associated with a lower risk of pneumococcal disease (relative risk 0.5 compared to no antiretroviral therapy).^540^ Pneumococcal vaccination has been shown to be immunogenic in patients receiving HAART, particularly at higher CD4 counts,^543^–^546^ and has not been shown to cause sustained viral load increases.^547^–^549^

We identified one randomized placebo-controlled trial of pneumococcal vaccination in 1,392 HIV-1 infected adults in Uganda (Evidence Table 2).^550^ The rate of invasive pneumococcal disease (HR 1.47, 95% CI 0.7–3.3) and all-cause pneumonia (1.89, 95% CI 1.1–3.2) was higher in the vaccine arm, with no significant effect on mortality. Extended (six years) follow-up of trial participants found that although vaccination continued to be associated with increased all-cause pneumonia (HR 1.6, 95% CI 1.0–2.4) it was also associated with an unexpected survival advantage (HR 0.84; 95% CI 0.7–1.0).^551^

Observational studies have primarily shown benefit from pneumococcal vaccination. Although a small (n=48) cohort study^552^ of Dutch intravenous drug users found a trend towards a higher risk of pneumonia in vaccinated patients, larger U.S. cohort^540^ and case-control studies^553^–^555^ found that vaccination, particularly in patients with higher CD4 counts, was associated with a lower risk of pneumococcal disease (Table 6).

Table 6 Effectiveness of Pneumococcal Vaccination in HIV-Infected Patients

Author, year | Setting | Sample size | Type of study | Results, vaccinated vs. unvaccinated
French, 2000^550^ | Uganda | 1392 | Randomized controlled trial | Invasive pneumococcal disease: HR 1.47; 95% CI 0.7–3.3
| | | | All pneumococcal events: HR 1.41; 95% CI 0.7–2.8
| | | | All-cause pneumonia: HR 1.89; 95% CI 1.1–3.2
| | | | Death: HR 1.08; 95% CI 0.87–1.33
Watera, 2004^551^ | Uganda | 1184 | 6-year follow-up of randomized controlled trial | Invasive pneumococcal disease: HR 1.28; 95% CI 0.7–2.2
| | | | All pneumococcal events: HR 1.24; 95% CI 0.7–2.0
| | | | All-cause pneumonia: HR 1.56; 95% CI 1.0–2.4
| | | | Death: HR 0.84; 95% CI 0.7–1.0
Dworkin, 2001^540^ | USA | 39086 | Cohort | Pneumococcal disease episodes in patients with CD4 cell count >500 cells/mm^3^: Adjusted RR 0.5, p<0.05
Lindenburg, 2001^552^ | The Netherlands | 48 | Cohort | All-cause pneumonia: RR 1.01; 95% CI 0.53–1.91
Breiman, 2000^554^ | USA | 176 cases | Case-control | Hospitalized for invasive pneumococcal infection: OR 0.59; 95% CI 0.38–0.91
| | 327 controls
Guerrero, 1999^555^ | USA | 127 cases | Nested case-control | All cause pneumonia: Adjusted OR 0.31; 95% CI 0.16–0.62
| | 127 controls
Gebo, 1996^553^ | USA | 85 cases | Nested case-control | Acute febrile illness and culture positive for Streptococcus pneumoniae in patients with CD4 cell count >200 cells/mm^3^: Adjusted OR 0.22; 95% CI 0.05–0.98
| | 85 controls

HR=hazards ratio; RR=relative risk; OR=odds ratio; CI=confidence interval

Influenza vaccination has been shown to be immunogenic in HIV-infected patients^556^–^560^ and is recommended annually.^17^ Although transient increases in HIV viremia have been observed after influenza vaccination,^561,^ ^562^ this observation has not been consistent,^563^–^566^ and a large cohort study of 36,050 HIV-positive patients found no negative long-term effects of influenza vaccination on CD4 counts, viral load, or clinical outcomes.^567^ We identified one good-quality randomized controlled trial evaluating the effectiveness of influenza vaccination in 102 HIV-infected patients in an outpatient military clinic (Evidence Table 2).^568^ It found that influenza vaccination was associated with a lower risk of respiratory symptoms (49% vs. 29%; p=0.04) and laboratory confirmed symptomatic influenza (18% vs. 0%; p<0.001) in the 3 months after immunizations.

We identified no studies estimating the number of newly diagnosed HIV patients who otherwise would not meet recommendations for influenza or pneumococcal vaccinations. Influenza and pneumococcal vaccination rates among HIV-infected persons in the U.S. were estimated at 8% to 40% in two large U.S. cohorts from the early 1990's.^569,^ ^570^

Studies have evaluated the safety and immunogenicity of hemophilus influenzae,^571,^ ^572^ hepatitis B virus,^573^–^580^ hepatitis A virus,^581^–^586^ and measles^587^ vaccinations. Although we identified no randomized trials estimating the effectiveness of these or other immunizations in improving clinical outcomes in HIV-infected patients, one longitudinal U.S. study of 16,248 HIV-infected persons found that the incidence of acute hepatitis B virus infection was lower in those who had received >=1 dose of hepatitic B virus vaccine (RR=0.6; 95% CI 0.4–0.9; overall rate 12.2 cases/1000 person-years).^588^ Because HIV-infected persons generally have a better antibody response when they are less immunocompromised, screening could improve the efficacy of immunizations by identifying them at earlier stages of disease.^589^ We identified no studies estimating the impact of screening on the effectiveness of vaccinations.

### Routine monitoring and follow-up

HIV-positive patients might benefit from periodic medical care to identify early signs of disease or earliest eligibility for interventions by monitoring CD4 counts and viral loads. We identified no studies estimating the benefits of routine monitoring and follow-up on health outcomes, though an increased frequency of outpatient visits may be associated with a greater likelihood of receiving HAART.^386^

### Prophylaxis for opportunistic infections

Although the incidence of nearly all AIDS-defining opportunistic infections has declined in the HAART era, prophylaxis remains an important intervention in patients with advanced immunodeficiency.^590^–^592^ In one large cohort study, a history of preventable opportunistic infection was associated with a chronic mortality rate of 66.7 per 100 person-years, compared to 2.3 per 100 person-years in those without an opportunistic infection (adjusted relative hazard 7.0 [95% CI 5.8–8.3]).^593^

Pneumocystis carinii pneumonia (PCP). PCP prophylaxis is recommended for all HIV-infected patients with a CD4 count <200 cells/mm3.^17^ Approximately 18% of untreated persons with a CD4 count <200 cells/mm3 develop PCP by 12 months, and 33% by 36 months.^594^ PCP is associated with decreased short-term survival, although this is attenuated by the use of HAART.^595^ We identified two good-quality systematic reviews of studies of primary prophylaxis for PCP (Evidence Table 3).^596,^ ^597^ They found that prophylaxis was effective in preventing PCP (RR 0.39, 95% CI 0.27–0.55),^597^ and that sulfamethoxazole-trimethoprim was more effective than aerosolized pentamidine or dapsone-based regimens, though it caused more (primarily self-limited) side effects (Table 7). Prophylaxis was also associated with a nonsignificant mortality benefit (RR 0.87, 95% CI 0.60–1.25).^597^ Although trimethoprim-sulfamethoxazole has been associated with a lower rate of bacterial infections in observational studies,^598^ we identified one clinical trial that found no differences in rates of bacteremia, pneumonia, and sinusitis or otitis.^599^ In two systematic reviews and two other clinical trials, lower doses of trimethoprim-sulfamethoxazole were associated with a lower rate of adverse events and slightly decreased efficacy compared to higher doses (Evidence Table 4).^596,^ ^597,^ ^600,^ ^601^ Other clinical trials found that atovaquone^602^ and pyrimethamine plus sulfadoxine were effective for PCP prophylaxis.^603^ One trial of azithromycin for Mycobacterium avium intracellulare prophylaxis also evaluated PCP as a secondary outcome and found that it was effective and had beneficial effects when added to standard PCP regimens.^604^

Table 7 Effectiveness of Primary Prophylaxis for Pneumocystis Pneumonia and Toxoplasmosis in HIV-Infected Patients

Regimen comparison | Pneumocystis pneumonia: relative risk (95% confidence interval) | Cerebral toxoplasmosis: relative risk (95% confidence interval) | Mortality outcomes: relative risk (95% confidence interval) | Source
Any primary prophylaxis vs. placebo | 0.39 (0.27–0.55) | Not reported | 0.87 (0.60–1.25) | Ioannidis, 1996*^†^ ^597^
Trimethoprim/sulfamethoxazole vs. aerosolized pentamidine | 0.59 (0.45–0.76) | 0.78 (0.55–1.11) | 0.88 (0.74–1.06) | Bucher, 1997*^596^
| 0.58 (0.45–0.75) | Not reported | 0.99 (0.80–1.22) | Ioannidis, 1996*^†^ ^597^
Dapsone-based regimen vs. aerosolized pentamidine | 0.90 (0.71–1.15) | 0.72 (0.54–0.97) | 1.07 (0.90–1.27) | Bucher, 1997*^596^
| 0.93 (0.72–1.19) | Not reported | 0.98 (0.86–1.12) | Ioannidis, 1996*^†^ ^597^
Trimethoprim/sulfamethoxazole vs. dapsone-based regimen | 0.49 (0.26–0.92) | 1.17 (0.68–2.18) | 1.08 (0.88–1.25) | Bucher, 1997*^596^
| 0.61 (0.34–1.10) | Not reported | 0.95 (0.82–1.11) | Ioannidis, 1996*^†^ ^597^
Atovaquone vs. dapsone | 0.81 (0.58–1.12) | 1.18 (0.26–5.30) | 1.25 (0.98–1.59) | El-Sadr, 1998^602^
Dapsone vs. pyrimethamine/sufadoxine | 0.87 (not significant) | 1.07 (not significant) | 1.15 (not significant) | Payen, 1997^603^
Azithromycin vs. rifabutin in patients already receiving pneumocystis prophylaxis | 0.42 (0.24–0.76) | Not reported | Not reported | Dunne, 1999^604^

* systematic review

† includes studies of secondary prophylaxis

Toxoplasmosis. Prophylaxis for toxoplasmosis is recommended for HIV-infected patients who are positive for toxoplasma IgG antibody and have a CD4 count <100 cells/mm3.^17^ Several medications used for PCP prophylaxis are also effective for toxoplasmosis prophylaxis (Evidence Tables 3 and 4). One good-quality systematic review found that dapsone was superior to trimethoprim-sulfamethoxazole, though both reduced the incidence of toxoplasmosis, and aerosolized pentamidine was not effective (Table 7).^596^

Tuberculosis. Tuberculosis prophylaxis is recommended for all HIV-infected patients with a positive purified protein derivative (PPD) test.^17^ We identified two systematic reviews that evaluated the effectiveness of TB prophylaxis in patients with chronic HIV infection (Evidence Table 5).^605,^ ^606^ Both found that isoniazid prophylaxis was effective compared to placebo at preventing tuberculosis (risk reduced by 60–86%) and death (risk reduced by 21–23%) in patients with a positive skin test, but had no beneficial effect in patients with a negative skin test (Table 8). Isoniazid was similarly effective alone or in combination with rifampin or rifampin plus pyrazinamide.^606^ Because of an association with increased liver toxicity, however, the combination of rifampin plus pyrazinamide is no longer recommended.^607^

Table 8 Effectiveness of Primary Prophylaxis for Tuberculosis in HIV-Infected Patients with A Positive Purified Protein Derivative Test

Regimen Comparison | Active tuberculosis | Mortality | Source
Any primary prophylaxis vs. placebo | OR 0.24 (95% CI 0.14–0.40) | OR 0.77 (95% CI 0.58–1.03) | Wilkinson, 2003^606^ (5 trials)
| RR 0.40 (95% CI 0.24–0.65) | RR 0.79 (95% CI 0.37–1.70) | Bucher, 1999^605^ (5 trials)
Isoniazid vs. placebo | OR 0.35 (95% CI 0.21–0.59) | OR 0.70 (95% CI 0.50–0.98) | Wilkinson, 2003^606^ (4 trials)
| RR 0.40 (95% CI 0.24–0.65) | RR 0.79 (95% CI 0.37–1.70) | Bucher, 1999^605^ (5 trials)
Isoniazid plus rifampicin vs. placebo | OR 0.36 (95% CI 0.17–0.75) | OR 0.71 (95% CI 0.49–1.04) | Wilkinson, 2003^606^ (1 trial)
Isoniazid plus rifampicin plus pyrazinamide vs. placebo | OR 0.48 (95% CI 0.24–0.99) | OR 0.90 (95% CI 0.61–1.31) | Wilkinson, 2003^606^ (1 trial)
Isoniazid vs. rifampicin plus pyrazinamide | OR 1.07 (95% CI 0.69–1.67) | OR 1.12 (95% CI 0.92–1.38) | Wilkinson, 2003^606^ (3 trials)

Mycobacterium avium intracellulare complex (MAC). Chemoprophylaxis against disseminated MAC disease is recommended for HIV-infected patients with a CD4 count of <50 cells/mm3.^17^ We identified 4 placebo-controlled trials^608^–^610^ and 2 head-to-head trials^611,^ ^612^ of primary prophylaxis (Table 9, Evidence Table 6). Rifabutin (2 trials, reported in one publication^610^), clarithromycin,^609^ and azithromycin^608^ were all effective compared to placebo in preventing disseminated MAC. Only clarithromycin was associated with a significant mortality benefit (HR 0.75, 95% CI 0.58–0.97),^609^ though prolonged open-label follow-up of clinical trials^610^ of rifabutin prophylaxis also suggested a survival advantage (relative hazard 0.74, 95% confidence interval 0.60–0.91).^613^ Head-to-head trials found that clarithromycin^611^ and azithromycin^612^ were superior to rifabutin for disseminated MAC, and were also more effective against other bacterial diseases. Combination therapy was not associated with a survival advantage compared to monotherapy.

Table 9 Effectiveness of Primary Prophylaxis for Disseminated Mycobacterium Avium Intracellulare Infection in HIV-Positive Patients

Regimen comparison | Disseminated MAC | Mortality | Source
Azithromycin vs. placebo | HR 0.34, p=0.004 | HR 1.02, p=0.955 | Oldfield, 1998^608^
Clarithromycin vs.placebo | HR 0.31 (95% CI 0.18–0.53) | HR 0.75 (95% CI 0.58–0.97) | Pierce, 1996^609^
Rifabutin vs. placebo | RR 0.43 (95% CI 0.26–0.70) | RR 0.68 (0.43–1.06) | Nightingale, 1993^610^ (Studies 0234 and 027)
| RR 0.47 (95% CI 0.29–0.77)
Clarithromycin vs. rifabutin | RR 0.56 (95% CI 0.37–0.85) | RR 0.97 (0.78–1.20) | Benson, 2000^611^
Azithromycin vs. rifabutin | HR 0.53 (0.34–0.85) | No differences | Havlir, 1996^612^
Clarithromycin plus rifabutin vs. rifabutin | RR 0.43 (0.27–0.69) | No differences | Benson, 2000^611^
Azithromycin plus rifabutin vs. rifabutin | HR 0.28 (0.16–0.49) | No differences | Havlir, 1996^612^
Azithromycin plus rifabutin vs. azithromycin | HR 0.53 (0.29–0.95) | No differences | Havlir, 1996^612^
Clarithromycin plus rifabutin vs. clarithromycin | RR 0.79 (0.48–1.31) | No differences | Benson, 2000^611^

Cytomegalovirus (CMV). Primary prophylaxis for CMV disease can be considered for HIV-infected adults and adolescents who are CMV antibody positive and have a CD4 count <50 cells/mm3.^17^ In the HAART era, persistent CMV viremia continues to be associated with poor clinical prognosis.^614^ We identified three placebo-controlled trials of primary prophylaxis for invasive CMV disease that assessed clinical outcomes (Evidence Table 7).^615^–^617^ One trial^617^ found that ganciclovir was associated with decreased risk of CMV disease (RR 0.51, 95% CI 0.36–0.73), but another^615^ found no significant benefit (HR 0.92, 95% CI 0.65–1.27). Ganciclovir was not associated with a significant mortality benefit in either trial and was associated with significant adverse events. The third trial found that valacyclovir was associated with an increased risk of CMV and trend towards increased death.^616^

### Papanicolaou smear

HIV infection in women is associated with an incidence of cervical cytology abnormalities 3–7 times higher than uninfected controls.^618^–^620^ Two recent U.S. prospective cohort studies reported an incidence of low-grade squamous intraepithelial lesions or higher-grade lesions of 8.1 and 8.9/100 person-years.^620,^ ^621^ The rates of cancer were 0/328 over 3 years and 0.4% (8/1143) over up to 5 years. High viral load and low CD4 count have both been associated with a higher incidence of cervical cytology abnormalities.^620^–^622^

Current guidelines recommend Pap smear twice within the first year after diagnosing HIV infection, and yearly after that if the results are normal.^17^ We identified no clinical trials or observational studies estimating the effects of more intense cervical cancer screening in HIV-infected women. Although small observational studies^623,^ ^624^ suggest that HAART may be associated with regression of cervical dysplasia, an Italian cohort study found that the incidence of invasive cervical cancer increased after 1995 and may be related to increased longevity of HIV-infected persons.^625^

## Key Question 7b. In Asymptomatic Patients with HIV Infection, Does Immediate Antiretroviral Treatment Result in Improvements in Clinical Outcomes Compared to Delayed Treatment Until Symptomatic?

Initiation of HAART in asymptomatic patients must be weighed against potential harms including effects on quality of life, long-term adverse events, and the development of resistance.^14^ Starting therapy when patients are asymptomatic could lead to long periods of treatment in which it is unlikely that clinical progression would occur. An analysis of different thresholds for initiating HAART estimated that the mean number of years between initiation of therapy and when disease progression would have occurred in the absence of treatment ranged from 4.81 years if HAART was started at the initial visit to 2.72 years if it was started when CD4 counts dropped below 500 cells/mm3.^626^

Although clinical trials of zidovudine monotherapy found no sustained benefit for immediate treatment in asymptomatic patients,^627^–^630^ good-quality randomized controlled trials^631^–^633^ and observational studies^88,^ ^634^–^640^ have consistently found HAART effective in reducing clinical progression and mortality compared to placebo or less-intensive regimens in patients with CD4 counts <200 cells/mm3. Under current U.S. guidelines, it is recommended that all HIV-infected asymptomatic persons with a CD4 count <200 cells/mm3 be offered HAART.^14^ Current guidelines also recommend considering treatment in asymptomatic patients with a high risk of disease progression based on CD4 counts (<350 cells/mm3) or viral loads (>100,000 copies/ml).^87,^ ^88,^ ^93,^ ^636,^ ^641,^ ^642^

We identified twelve observational studies (no clinical trials) evaluating the risk of disease progression or death in asymptomatic patients initiating HAART therapy at different CD4 count thresholds above 200 cells/mm3. Because the rate of disease progression in patients with CD4 counts >500 cells/mm3 is very low, most studies evaluated clinical outcomes in patients initiating HAART at lower CD4 counts. All of these studies were relatively short-term (longest 4 years) and could underestimate the risks of long-term adverse events or the development of resistance. In addition, observational studies that do not control for lead-time bias from evaluating patients with different initial CD4 counts could overestimate the benefits of early HAART.^643^

To control for lead-time bias, four cohort studies identified cohorts of patients at initial CD4 count strata and evaluated them according to when they received HAART (Evidence Table 8).^638^–^640,^ ^644^ A Swiss study that found a benefit for starting at CD4 counts above 350 cells/mm3 did not stratify results of patients who started above or below CD4 counts of 200 cells/mm3.^644^ Three U.S. studies found no significant benefit associated with starting HAART at CD4 counts between 350 and 500 cells/mm3 versus between 200 and 350 cells/mm3 (Table 10).^638^–^640^ Another U.S. study that did not control for lead-time bias, but evaluated rates of clinical progression in the subset of patients who achieved durable virologic suppression after initiating HAART, reported similar findings.^645^

Table 10 Studies Evaluating When to Initiate Antiretroviral Therapy in HIV-Infected Patients

CD4 count (cells/mm^3^) at which HAART started | Clinical progression or mortality | Mortality | Source
501–750 vs. <500 | Not reported | Rate ratio 1.20 (0.17–8.53) | Palella, 2003^638^
351–500 vs. 200–350 | Not reported | Rate ratio 0.61 (0.22–1.67) | Palella, 2003^638^
| RH 0.95, p=0.897 | Not reported | Ahdieh-Grant, 2003^639^
| p=0.40, log-rank test* | Not reported | Sterling, 2003^645^
350–499 vs. <350 | p=0.21, log-rank test | p=0.10, log-rank test | Sterling, 2003^640^
>350 vs. <350 | HR 0.28 (0.12–0.68) | HR 0.20 (0.07–0.52) | Opravil, 2002^644^
350–499 vs. <200 | RH 0.37, p=0.003 | Not reported | Ahdieh-Grant, 2003^639^
| p=0.01, log-rank test* | Not reported | Sterling, 2003^645^
201–350 vs. <200 | Not reported | Rate ratio 0.27 (0.14–0.55) | Palella, 2003^638^
| RH 0.39, p<0.001 | Not reported | Ahdieh-Grant, 2003^639^
| p=0.09, log-rank test* | Not reported | Sterling, 2003^645^

* In patients achieving durable viral suppression

Of the seven cohort studies that did not control for lead-bias, the largest was a collaborative analysis of 12,574 patients from 13 cohorts.^88^ The risk for AIDS or death overlapped for patients starting at CD4 counts between 200–349 cells/mm3 (adjusted hazard ratio 0.24 versus starting at CD4 count <50 cells/mm3, 95% CI 0.20–0.30) and for those starting at >=350 cells/mm3 (AHR 0.18, 95% CI 0.14–0.22). Four^88,^ ^634,^ ^636,^ ^641,^ ^645^ of six^637,^ ^646^ smaller studies found a benefit or trend toward benefit from initiation of treatment at CD4 counts above versus below 350 cells/mm3, particularly at higher viral loads. A recent observational study of U.S. injection drug users used the novel approach of stratifying HIV-positive patients according to CD4 count and receipt of HAART, and comparing survival to HIV-negative drug users.^647^ It found that survival of HIV-positive injection drug users approximated that of uninfected controls only if their CD4 counts were >350 cells/mm3 and they were receiving HAART. On the other hand, there were no significant differences in survival between HIV-infected injection drug users receiving or not receiving HAART when CD4 counts were >200 cells/mm3.

Observational studies may not account for important underlying factors that affect the decision to initiate HAART. A recent cohort study, for example, found that all patients with CD4 counts of >200 cells/mm3 and at least 75% adherence had greater than 90% 48-month survival after initiating HAART.^646^ Another study showed that increased physician experience predicted a lower rate of clinical outcomes.^415^ Other cohort studies did not evaluate these variables as potential confounders.

A randomized clinical trial (The Strategies for Management of Antiretroviral Therapies trial) comparing immediate maximal viral suppression in asymptomatic patients with a CD4 count >350 cells/mm3 versus delay until counts drop below 250 cells/mm3 is in progress, with preliminary results expected in 5 to 7 years.^648^

## Key Question 7c. How Well Do Interventions Reduce the Rate of Viremia, Improve CD4 Counts, or Reduce Risky Behaviors?

### Viral loads and CD4 counts

HAART regimens are much more effective than less intensive regimens in producing durable viral suppression and sustained increases in CD4 cell counts.^631,^ ^649^–^651^ Sustained suppression below the lower detection limit of the most sensitive assay available (currently <50 copies/ml in clinical settings) is the standard for measuring treatment success.^14,^ ^174,^ ^652,^ ^653^ Reductions in plasma viral loads with antiretroviral therapy are also associated with reductions in HIV-1 levels in genital secretions.^505,^ ^506^

We identified one fair-quality (did not assess quality of included studies) systematic review evaluating the effectiveness of different HAART regimens in achieving viral suppression in 23 clinical trials (3,257 antiretroviral naïve patients) of HAART versus 2-drug regimens.^654,^ ^655^ The percentage of patients on HAART with HIV viral load <=50 copies/ml at 48 weeks was 47% (95% CI, 43–51%) overall, 45% (35–54%) for triple NRTI therapy, 46% (41–52%) for PI-based therapy, and 51% (43–59%) for NNRTI-based therapy.^654^ CD4 cell count increase at 48 weeks averaged 160 cells/mm3 and did not differ between regimens. Smaller fair-quality (did not assess quality of studies or search strategy not clear) meta-analyses of nevirapine-based HAART^656^ and once-a-day regimens^655^ that included observational studies and abstracts reported somewhat higher virologic response rates, ranging from 70% to 91%.

We identified 34 published head-to-head trials comparing different HAART regimens in antiretroviral naïve or minimally experienced patients (Table 5, Evidence Table 1). The rate of complete viral suppression (<5 to <50 copies/ml) at 24 weeks to 3 years ranged from 21% to 83%. CD4 cell count increases ranged from 89 to 283 cells/mm3. Differences observed in intermediate outcomes from head-to-head comparisons of specific HAART regimens are used to regularly update guidelines on use of antiretroviral therapy in HIV-infected persons.^14,^ ^15^

HAART can achieve durable improvements in intermediate outcomes. In one study, 47% (14 of 30) patients originally enrolled into a trial of HAART had a viral load <50 copies/ml after six years.^423^ Other long-term observational studies indicate that 40% to 50% of patients on HAART reach and maintain CD4 counts >500 cells/mm3 for 4–5 years,^414,^ ^657^ though initial large CD4 count increases may become attenuated after the first 18 months even in persons with undetectable viral loads.^658^ The longest head-to-head clinical trial of HAART regimens found that >60% of patients had a viral load <50 copies/ml after 3 years.^472^

### Effects of counseling on risky behaviors

We identified three recent systematic reviews on the effects of counseling and testing for HIV on behavior changes.^659^–^661^ One good-quality systematic review of 35 studies found mixed results, which varied according to the population studied (Evidence Table 9).^661^ The most consistent evidence on beneficial effects of counseling and testing came from multiple studies of heterosexual HIV-serodiscordant couples that consistently found increased condom use. In addition, tested persons who were HIV-positive were more likely to adopt less risky behaviors than those who were HIV-negative or untested. On the other hand, studies were inconsistent with regard to condom or other birth control method use in HIV-infected women, and two studies found no impact on composite risk behavior scores. In intravenous drug users, most studies showed reductions in drug related and high-risk sexual practices after HIV counseling and testing. In men who have sex with men, there was no consistent evidence on the effects of HIV counseling and testing. An earlier, fair-quality systematic review reported similar findings.^659^

A more recent, good-quality systematic review also calculated effect sizes (the standardized mean difference index, d+) for sexual risk behaviors (unprotected intercourse, condom use, and number of sexual partners) before and after HIV counseling and testing from 27 studies published through 1997 with 19,527 participants.^660^ The weighted mean effect sizes for unprotected intercourse were greater for HIV-positive persons (d+=0.47; 95% CI 0.32, 0.61) and serodiscordant couples (d+=0.75; 95% CI 0.59–0.92) than for untested participants (d+=0.16; 95% CI 0.07, 0.25), but HIV-negative participants did not reduce their frequency of unprotected intercourse. Similar results were reported for condom use. Neither HIV-positive nor HIV-negative persons exhibited greater changes than untested persons in the number of sexual partners.

Findings of all of the systematic reviews were limited by the quality and type of available data.^659^–^661^ In general, the content and duration of counseling provided was poorly described and varied dramatically between studies. Most studies employed older counseling approaches and measured self-reported behavior changes. Some studies had serious methodological limitations, often because they addressed the impact of HIV counseling as a secondary issue. Most studies did not make a distinction between unprotected sex with serodiscordant partners or partners of unknown serostatus and unprotected sex with patients with known concordant serostatus.

We identified several recent (published after 1997) non-comparative studies on the effects of HIV counseling and testing on risky behaviors in HIV-positive persons. A cross-sectional study from three states found that 81% to 93% of patients with a recent HIV-seropositive diagnosis self-reported safer sexual behaviors.^662^ Only 180 of 543 eligible patients participated, however, which could have biased the findings. Another study reported reduced risky behavior among serodiscordant couples who participated in counseling following HIV diagnosis.^663^ Similarly, a recent cohort study showed that receiving an HIV positive test result was associated with a significant reduction in unprotected anal intercourse in HIV-positive men who have sex with men.^664^ In contrast, a small cross-sectional study found that men who reported their most recent HIV test as positive were three times more likely to have engaged in unsafe sex compared to those who did not know they were HIV positive.^665^

Effects of HIV counseling and testing on risky behaviors in adolescents have not been well studied. In one observational study of adolescent females, HIV-infected persons were more likely to report 100% partner condom use in the last 3 months compared to uninfected at-risk persons (OR 3.3; 95% CI 1.7–5.6).666 Another observational study, however, found that 43% of sexually active HIV-infected adolescents reported having unprotected sex at last intercourse despite regular primary care, but did not compare rates before and after HIV diagnosis.^667^

More intensive, targeted, or focused counseling could be more effective than standard counseling in HIV-infected persons. We identified nine fair-quality randomized trials evaluating different counseling methods. Eight^537,^ ^668^–^674^ evaluated more intensive versus standard or less intensive counseling; the ninth^675^ evaluated different brief counseling approaches emphasizing negative consequences, positive consequences, or medication adherence. In general, all studies showed that risky behavior decreased with any counseling for outcomes such as decreased unsafe sexual activity;^537,^ ^668,^ ^669,^ ^673^–^675^ fewer sexual partners;^669,^ ^672^ more consistent condom use;^537,^ ^668,^ ^671^ and increased refusal of unsafe sex.^670^ Six^537,^ ^668,^ ^669,^ ^672^–^674^ of the eight^670,^ ^671^ studies showed that more intensive counseling was associated with greater reductions in risky behavior compared to standard or less-intense counseling. The ninth study found that brief counseling that emphasized negative consequences was associated with a greater reduction in risky behaviors than brief counseling that emphasized positive consequences or medication adherence.^675^

There is little evidence regarding the effect of HIV counseling and testing on risky drug behaviors. Since the start of the epidemic, riskier drug use behaviors in the U.S. have declined for both HIV-infected and uninfected injection drug users.^676^–^679^ One randomized trial found that HIV testing and counseling of injection drug users was not associated with decreased involvement in high-risk behaviors compared to AIDS education alone or no immediate intervention.^680^ A prospective study found that recent testing and HIV-positive status in intravenous drug users were not associated with changes in high-risk behaviors compared to untested or tested HIV-negative persons.^681^ In both studies, all participants decreased their high-risk behaviors. On the other hand, a randomized trials of HIV-infected drug users in a methadone maintenance program^682^ and of HIV-infected adolescent drug users^668^ found that those who received more intense counseling reduced risky drug use behaviors more than those who received standard counseling Observational studies from the U.S. and Europe have also found that drug users who knew they were HIV-positive reported less risky behaviors than those who were untested or not infected.^683^–^685^ A recent observational study of a mixed population of infected and uninfected injection drug users in Chicago found that regular needle exchange program use was associated with less risky behaviors.^686^

## Key Question 8. What are the Harms Associated with Antiretroviral Therapy?

Individual antiretroviral drugs, drug classes, and drug combinations are all associated with specific adverse event profiles.^14^ Retrospective U.S. cohort studies found that 61% of antiretroviral naïve patients had changed or discontinued their initial HAART regimen by eight months^687^ and the median duration they remained on their initial regimen was less than two years,^688^ with 40–50% discontinuing due to adverse events. Many antiretroviral-associated adverse events, however, are short term or resolve after the offending drug or drug combination is discontinued, and effective alternatives can often be found.^15^ In a six-year follow-up study from a clinical trial, for example, 58% (7 of 12) patients who discontinued the original HAART regimen had viral suppression <500 copies/ml on another antiretroviral regimen.^423^ Detailed and regularly updated guidelines reporting adverse events associated with specific antiretroviral drugs, drug classes, and combinations are available.^14^ Certain antiretroviral drugs and combinations (such as stavudine plus didanosine^434,^ ^484,^ ^689^) are no longer recommended as first-line therapy because of specific associations with adverse events.

A recent good-quality systematic review comparing HAART to dual and monotherapy regimens found that 26 out of 54 trials gave information on drug-related withdrawals, a marker for intolerable or severe adverse events.^421^ Dropout rates were higher with one-drug therapy than with placebo, but no differences were seen between two- and one-drug therapy. In eight trials comparing three-drug therapy with a PI to two-drug therapy without a PI, there was a significantly higher pooled dropout rate with three-drug therapy (Peto Odds ratio 1.39, 95% CI 1.03–1.87), but there were no significant differences between three- and two-drug therapy without PI's from four trials (Peto OR 0.80, 95% CI 0.42–1.51) or three- and two-drug therapy with PI's from two trials (Peto OR 1.17, 95% CI 0.84–1.63).

Of 34 published head-to-head trials of HAART regimens in antiretroviral naïve patients, 33 reported withdrawal rates due to adverse events, changes in medication regimen due to adverse events, or rates of discontinuation of study medications (Table 5, Evidence Table 1). Because included trials used different definitions for withdrawal due to adverse events (for example, some did not consider substitution with a pre-specified antiretroviral a withdrawal) and varied in length, rates across trials ranged widely (0% to 46%) and were not directly comparable. Although several trials reported significant differences in withdrawal due to adverse event rates between specific HAART regimens,^432^–^434,^ ^484,^ ^486,^ ^491^ there was no consistent pattern suggesting that any type of HAART regimen was associated with fewer withdrawals due to adverse events. In trials comparing PI-and NNRTI-based three-drug regimens, for example, withdrawal rates due to adverse events were similar for three out of four trials.^477,^ ^483,^ ^491,^ ^493^ Four-drug regimens were not associated with significantly increased withdrawal rates due to adverse events compared to three-drug regimens in six trials.^431^–^435,^ ^470^ In all trials, fatal adverse events were rare or none were reported.

Evidence about the prevalence of adverse events associated with HAART in clinical practice is available from a large (n=1,160), good-quality Swiss cohort study.^690^ 47% of patients reported a clinical and 27% a laboratory adverse event probably or definitely attributed to HAART within the last 30 days. Among these, 9% and 16% respectively were graded as serious or severe. Single-PI and PI-sparing antiretroviral treatment were associated with a comparable prevalence of adverse events. Compared with single-PI treatment, dual-PI antiretroviral treatment (OR 2.0, 95% CI, 1.0–4.0) and triple class HAART regimens (OR 3.9, 95% CI, 1.2–12.9) were associated with increased adverse events.

HAART is associated with metabolic disturbances (the lipodystrophy syndrome, ^691^–^702^ hyperlipidemia^703^–^711^ and diabetes or hyperglycemia^712^–^717^) that are associated with an increased risk for cardiovascular events. Although all antiretroviral-associated metabolic disturbances impact quality of life, the lipodystrophy syndrome could have a particularly negative impact because of its effects on body morphology.^718^ The only published study using a standardized quality of life instrument, however, did not find an association between the presence of lipodystrophy and decreased overall quality of life.^719^ Although primarily associated with protease inhibitor use,^720,^ ^721^ more recent studies have also found associations between antiretroviral agents from other classes and metabolic disturbances.^472,^ ^693,^ ^694,^ ^713,^ ^722^–^730^ The effects of HAART-associated metabolic abnormalities may be ameliorated by changes in the regimen or appropriate treatment.^731^–^738^

The largest prospective study on the risk of cardiovascular events associated with both PI- and non-PI-based combination antiretroviral therapy regimens was a good-quality collaborative analysis of 23,468 patients enrolled in 11 cohorts with 36,199 patient-years of follow-up (Table 11, Evidence Table 10).^739^ It found that during the first four to six years of use, the incidence of myocardial infarction increased with longer exposure to combination antiretroviral therapy (adjusted relative rate per year of exposure, 1.26 [95% CI, 1.12 to 1.41]). The overall rate of myocardial infarction, however, was low, at 3.5 events/1,000 person-years, and the rate was 0.5 events/1,000 person-years in persons not on HAART. The risk of all cardio- and cerebrovascular disease events (myocardial infarction, invasive cardiovascular procedures and stroke) was similar to the risk for myocardial infarction alone (RR per year of exposure, 1.26 [95% CI, 1.14–1.38]), though the rate of events was higher (5.7/1,000 person-years overall and 1.2/1000 person-years in persons not on HAART).^740^ The risk of myocardial infarction on HAART was substantially higher than estimated using baseline cardiovascular risk data.^741^ This study had insufficient power to assess the risk associated with different antiretroviral drugs and classes but is ongoing.

Table 11 Studies* Assessing The Risk of Cardiovascular Complications Associated with Antiretroviral Therapy in HIV-Positive Patients

Author, year | Setting | Sample size | Type of study | Risk associated with HAART | Rate of cardiovascular complications
Coplan, 2003^742^ | USA | 10986 HIV-infected persons enrolled into clinical trials evaluating PI's | Meta-analysis of clinical trials | Myocardial infarction, PI-containing vs. NRTI-only regimen: Relative risk 1.69 (95% CI 0.54–7.48) | Myocardial infarction: 1.31 per 1000 person-years in randomized phases and 1.63/1000 person-years in extension phases
Barbaro, 2003^745^ | Italy | 1551 HIV-infected persons receiving antiretroviral treatment | Prospective cohort | Coronary artery disease-related events, receiving PI vs. no PI: RR 11.5 (95% CI 2.72–48.55, p<0.001) | Myocardial infarction
| | | | | Receiving PI: 5.1/1000 person-years
| | | | | Not receiving PI: 0.4/1000 person-years
Friis-Moller, 2003^739^ and the Writing Committee of the DAD Study Group, 2004^740^ | Europe | 23468 HIV-infected persons | Prospective cohort | Myocardial infarction: Adjusted relative rate per year of exposure 1.26 (95% CI 1.12–1.41, p<0.001) for first 4–6 years | Myocardial infarction: 3.5 events per 1000 person-years
DAD Study | | | | Cardio- and cerebrovascular events (myocardial infarction, stroke, invasive cardiovascular procedures, death from other cardiovascular causes): Adjusted relative rate per year of exposure 1.26 (1.14–1.38, p<0.0001) | Cardio- and cerebrovascular events: 5.7 events per 1000 person-years
Holmberg, 2004^743^ and 2002^744^ | USA | 5672 HIV-infected persons taking PI or not on PI | Prospective cohort | Myocardial infarction, receiving PI vs. no PI: Hazards ratio 8.1 (95% CI 1.1–56.8, p=0.036) | Myocardial infarction rate
| | | | | 2000: 3.10 per 1000 person-years
| | | | | 2002: 1.91 per 1000 person-years
Mary-Krause, 2003^746^ | France | 34976 HIV-infected men | Prospective cohort | Myocardial infarction | Myocardial infarction (95% confidence interval) per 10000 person-years
| | | | 18–29 months PI vs. <18 months: Standardized morbidity ratio 1.9 (95% CI 1.0–3.1) | <6 months PI: 3.98 (0.08–7.89)
| | | | >=30 months PI vs. <18 months: Standardized morbidity ratio 3.6 (95% CI 1.8–6.2) | 6–11 months PI: 10.49 (3.64–17.35)
| | | | | 12–17 months PI: 11.24 (3.45–19.02)
| | | | | 18–23 months PI: 14.49 (4.45–24.53)
| | | | | 24–29 months PI: 17.86 (4.63–31.09)
| | | | | 30–35 months PI: 49.00 (21.28–76.72)
| | | | | >=36 months PI: 8.82 (0.00–26.01)
Currier, 2003^750^ | USA | 28513 HIV-infected persons and general Medicaid population | Retrospective cohort | Coronary heart disease, receiving PI vs. no PI: Adjusted relative risk 2.06 (p<0.001) | Coronary heart disease
| | | | | Men: 0.77 (18–24 years old) to 5.55 (75 years or older) cases per 100 person-years
| | | | | Women: 0.40 (18–24 years old) to 5.43 (65–74 years old) per 100 person-years
Jutte, 1999^747^ | Switzerland | 1324 HIV-infected persons receiving antiretroviral treatment | Retrospective cohort | Myocardial infarction, receiving PI ves. no PI: Relative risk (calculated) 5.05 (p=0.025) | Myocardial infarction rate
| | | | | Receiving PI: 1.06 per 100 patient-years
| | | | | Receiving antiretroviral treatment without PI: 0.21 per 100 patient-years
Klein, 2002^749^ | USA | 4159 HIV-infected persons taking PI or not on PI | Retrospective cohort | Coronary heart disease and myocardial infarction hospitalization rates, HIV-positive patients receiving PI vs. no PI and receiving antiretroviral therapy vs. no therapy: No significant differences | Myocardial infarction rate, HIV-positive vs. HIV-negative: 4.3 vs. 2.9/1000 person-year, p=0.07
Leport, 2002^748^ (Abstract only) | France | 223 HIV-infected persons starting PI and 527 controls from the general population | Retrospective cohort | Myocardial infarction, HIV men on PI vs. general population: RR 1.20 (p<0.00001) | Not reported

* Excluding ecologic studies evaluating time-trends in cardiovascular complication rates

NRTI Nucleoside Reverse Transcriptase Inhibitor

PI Protease Inhibitor

Other studies have primarily evaluated the cardiovascular risk associated with protease inhibitors. We identified a fair-quality meta-analysis of 30 clinical trials of the first four PI's that found a non-significant trend towards increased risk of myocardial infarction in patients on PI's, particularly with continued use after the end of the trial.^742^ We identified seven other prospective^743^–^745^ and retrospective^746^–^750^ cohort studies which also generally found an increased risk or trend towards increased risk for cardiovascular events in patients on PI's (Table 11). The largest study, for example, of 34,976 HIV-infected French men, found that PI exposure for more than 18 months was associated with a higher incidence of myocardial infarction (standardized morbidity ratio 1.9 [95% CI 1.0–3.1] for PI exposure 18–29 months versus <18 months and 3.6 [1.8–6.2] for PI exposure >=30 months versus <18 months).^746^ The one study that did not find a significant association between cardiovascular events and antiretroviral therapy did report an association between HIV-positive status and cardiovascular events.^749^ Ecologic studies evaluating trends over time in rates of cardiovascular events or procedures in HIV-infected patients in Italy^751^ and the U.S.^752^ reported a declining incidence since the introduction of HAART, but studies from Germany^753^ and Canada^754^ reported an increase. Interpretation of these studies was limited by potential confounding from changes in clinical practice over time, retrospective collection of data, and changes in the demographics of persons surviving with HIV infection, and were not included in the tables.^723^

### Adherence

Inadequate adherence to antiretroviral therapy is associated with poor clinical and intermediate outcomes.^755^–^761^ In a study of homeless patients on HAART, for example, no patients with high (>90% of pills taken) levels of adherence progressed to AIDS, compared to 8% with moderate (51%–90% of pills) and 41% with low (<=50% of pills) adherence.^760^ Even moderate (79–89%) nonadherence to HAART may be associated with viral rebound and the development of resistance.^762^ Estimates of average rates of non-adherence to antiretroviral therapy range from 50% to 70%, but are difficult to compare across studies because of differences in populations and lack of standardization of methods (pill counts, electronic monitoring systems of prescription bottles, patient self-report, or prescription refills rates) to measure adherence or define nonadherence.^763^ Furthermore, patients who are nonadherent with one regimen may be adherent with a less complex regimen or one associated with a different side effect profile, and adherence rates for individual patients change over time.^764^ Clinical trials may overestimate adherence in real-life settings because of participant bias and methods used in trials to maximize adherence.^765^

We identified one observational study of antiretroviral naïve patients initiating HAART in Canada that estimated adherence by the timing of prescription refills.^761^ It found that 355/1,422 (25%) of patients had <75% adherence, and 606/1,422 (43%) had <95% adherence over a median follow-up of 40.1 months. A fair-quality systematic review found that factors that were consistently associated with nonadherence were the presence of symptoms and adverse drug effects, psychologic distress, lack of social or family support, complexity of the HAART regimen, low patient self-efficacy, and inconvenience of treatment.^766^ Ongoing drug or alcohol use and low health literacy have also been associated with poor adherence.^767,^ ^768^

Increasing adherence levels could improve the efficacy of HAART regimens. A good-quality systematic review found only one study on patient support and education for promoting adherence to HAART that met inclusion criteria.^769^ It found that a pharmacist-led intervention consisting of educational counseling and availability of follow-up telephone support was associated with improved adherence at 24 weeks, but not better viral suppression rates.^770^ We identified another recent randomized trial that found that using an education intervention in addition to routine counseling was not associated with differences in adherence rates or intermediate outcomes at 24 weeks compared to routine counseling.^771^ Results of programs specifically aimed to improve adherence among HIV-infected adolescents, who may have higher rates of nonadherence,^772^ are not yet available.^773^

## Key Question 9. Have Improvements in Intermediate Outcomes (CD4 Counts, Viremia, Risky Behaviors) Been Shown to Reduce Premature Death and Disability or Spread of Disease?

### Premature death and disability

A recent good-quality study combining results of 13 prospective cohort studies from Europe and North America examined the relationship between intermediate response to HAART regimens (6-month CD4 count and plasma HIV-1 viral load) and clinical outcomes (development of AIDS-associated opportunistic illnesses or death) in 9,323 antiretroviral-naïve adults with HIV infection using intention-to-continue-treatment analyses.^436^ It found that six-month CD4 count and viral load remained strongly associated with progression after controlling for baseline levels and degree of change, demographic factors, drug class prescribed at baseline, and total number of drugs in the baseline regimen (three vs. four or more drugs). A 6-month CD4 count of >=350 cells/mm3 was associated with an adjusted hazard ratio of 0.18 (0.11–0.29) for AIDS or death and 0.13 (0.07–0.25) for death alone compared to <25 cells/mm3. A 6-month viral load of <=500 copies/ml (undetectable) was associated with a hazard ratio of 0.29 (0.21–0.39) for AIDS or death and 0.41 (0.27–0.63) for death compared to >=100,000 copies/ml. Other factors associated with a higher risk of AIDS or death were age >=50 years old, injection drug use, and CDC stage C at baseline or at 6 months. A model incorporating these variables estimated a probability of progression to AIDS or death at 3.5 years after starting HAART of 2.4% (95% confidence interval 1.8%–3.0%) in patients in the lowest risk stratum, compared to 83.1% (95% CI 72.4%–90.2%) in patients in the highest risk stratum. As reported in other studies, consideration of both intermediate markers improved prediction of clinical progression over either marker alone.^774^–^777^ Other recent cohort studies of antiretroviral naïve patients starting HAART^778,^ ^779^ and older trials of zidovudine monotherapy^780,^ ^781^ and dual antiretroviral therapy^774^–^776,^ ^782^–^785^ reported similar findings.

### Spread of disease

We identified seven studies evaluating the association between risk of heterosexual transmission of HIV-1 and viral load. The largest study, a good-quality prospective cohort of 415 serodiscordant couples in rural Uganda, a setting in which antiretroviral therapy was not available, found that viral load was the chief predictor for heterosexual transmission (male to female or female to male) of HIV-1.^52^ The rate of transmission in patients with HIV-1 viral load <1,500 copies/ml was zero out of 51, and increased in a dose-response fashion to 23.0 per 100 person-years in patients with a viral load >=50,000 copies/ml. The adjusted rate ratio for risk of transmission was 11.87 (95% CI 5.02–34.88) in patients with viral load >50,000 copies/ml compared to those with a viral load <3,500 copies/ml. A cross-sectional study of 490 couples from Thailand^786^ and smaller case-control^787^ and retrospective cohort studies.^50,^ ^51,^ ^788,^ ^789^ reported similar findings for heterosexual transmission. An earlier retrospective cohort study did not measure levels of plasma viremia, but found that advanced immunodeficiency (CD4 count <20 cells/mm3 or history of AIDS) was associated with increased heterosexual transmission.^790^

There are only limited data evaluating the association between changes in risky behaviors in HIV-positive persons and reduced risk of horizontal transmission. A recent systematic review found that consistent use of condoms, defined as use of a condom for all acts of penetrative vaginal intercourse, resulted in an 80% reduction in heterosexual transmission of HIV.^791^ Another pooled analysis found that condoms are 90% to 95% effective when used consistently, and that consistent condom users are 10 to 20 times less likely to become infected when exposed to the virus than are inconsistent or non-users.^792^

In mixed populations of infected and uninfected injection drug users, lower rates of HIV infection were associated with decreased reported risky drug use behaviors,^793^ participation in needle exchange programs,^794^ and participation in drug treatment programs.^795^ A large (n=4,419) cross-sectional study of injection drug users found that self-reported behavioral changes was associated with a protective odds ratio for HIV infection of 0.50 (95% confidence interval 0.42–0.59).^793^ We identified no studies, however, evaluating the association between reduction in risky drug use behaviors by HIV-infected persons and subsequent reduction in transmission rates.