# Methods

## Literature Search and Strategy

We searched the topic of HIV in the MEDLINE and Cochrane Library Databases. Most searches were carried out from 1983 (the year that HIV was characterized) through June 30, 2004. For searches on antiretroviral therapy, electronic searches on these databases were performed from 1998, the year that HAART was first recommended in U.S. guidelines,^175^ and supplemented by an electronic search for systematic reviews of antiretroviral therapies from 1983. We performed a total of 13 searches covering the areas of risk factor assessment, screening tests, work-up, and interventions. Detailed electronic search strategies and results are presented in Appendix 1. Periodic hand searching of relevant medical journals, the Centers for Disease Control web site, reviews of reference lists, and peer review suggestions supplemented the electronic searches. For rapid HIV tests, we included unpublished studies reported in manufacturer inserts. Abstracts were not included in systematic searches, but major abstracts cited in reference lists or presented at recent conferences were included. Reviews, policy statements, and other papers with contextual value were also obtained.

## Inclusion / Exclusion Criteria

A single reader reviewed all English abstracts. Papers were selected for full review if they were about HIV infection, were relevant to key questions, and met inclusion criteria. For all key questions, articles were limited to those that evaluated the general adult and adolescent population with chronic HIV infection. We excluded studies that only included overtly symptomatic or end-stage patients. Although the population of interest was persons with unsuspected HIV infection who would be identified by screening, we included studies of patients with a broad spectrum of chronic HIV disease in order to get a picture of the effects of screening and treatment in patients with different degrees of immune deficiency. We included studies performed in the U.S. or Australia, Canada and countries of Western Europe, in which the epidemiology and management of chronic HIV infection are similar. When important studies for a specific key question had only been performed in other countries, these were included as well. Studies of non-human subjects and those without original data were excluded. Foreign language papers were considered if they were clinical trials and an abstract was available in English. We searched for relevant systematic reviews for all key questions. Additional key question-specific inclusion criteria are listed in Appendix 2.

## Data Extraction and Synthesis

We used predefined criteria from the USPSTF to assess the internal validity of included systematic reviews, trials and observational studies, which we rated as “good,” fair," or “poor.” We also rated the applicability of each study to the population that would be identified by screening. The rating system was developed by the USPSTF and is described in detail elsewhere and summarized in Appendix 3.^176^ For included trials and systematic reviews, we abstracted information about setting, patients, interventions, and outcomes. For intervention studies, when available we abstracted intention-to-treat results with missing data classified as treatment failures.^174^ We presented full evidence tables for selected high-priority key questions, and more concise tables for other key questions. We rated the overall body of evidence for each key question using the system developed by the USPSTF.

## Size of Literature Reviewed

Investigators reviewed 5,993 abstracts identified by the searches (Appendix 4). From the searches, 1,866 full-text articles were reviewed. An additional 809 non-duplicate articles identified from reference lists, hand searches, and experts were also reviewed.

Appendix D. Search and Selection of Literature