# Introduction

This evidence synthesis focuses on screening for unsuspected human immunodeficiency virus (HIV) using HIV antibody (Ab) tests in non-pregnant adolescents (aged 13 to 18 years old) and adults. The review will be used by the U.S. Preventive Services Task Force (USPSTF) to make recommendations regarding screening in the general adult and adolescent population. An accompanying report will review evidence regarding screening in pregnant women.

Since the USPSTF published HIV screening recommendations in 1996, there have been substantial changes in the management and outcomes of chronic HIV infection. Although this report reviews the overall body of evidence regarding screening, it emphasizes recent data regarding the efficacy of highly active antiretroviral therapy (HAART) regimens, the accuracy and acceptability of new test methods, long-term risks of antiretroviral therapy, and the optimal timing of therapy in asymptomatic patients.

## Burden of Condition / Epidemiology

It is estimated that 850,000 to 950,000 persons in the United States are infected with HIV, with 405,926 known to be living with the acquired immunodeficiency syndrome or AIDS (defined as an AIDS-defining condition or CD4 count <200 cells/mm3 in persons with HIV infection)^1^ in 2003.^2,^ ^3^ Of those infected, 25% (180,000–280,000) are thought to be unaware of their positive status.^4^ The rate of unrecognized HIV infection is higher in specific subgroups, particularly young (15–22 years old) white (60%) and black (91%) men who have sex with men.^5^ In 2002, the rate of HIV infection without AIDS in the U.S. was 127.8/100,000 persons, and the rate of HIV infection with AIDS was 167.3/100,000 persons.^2^ Since 1992, the annual number of newly diagnosed HIV infections has been approximately 40,000, though there appeared to be a slight increase from 1999 to 2002.^6^ The number of newly diagnosed cases of AIDS is also approximately 40,000 annually.^3,^ ^7,^ ^8^ In 2003, about 12% of new diagnoses of HIV and AIDS in the U.S. were in persons between the ages of 13 and 24.^2^ Statistical modeling, however, suggests that approximately one-half of HIV-infected persons in the U.S. acquired their infection by age 25, and one-quarter by age 22.^9^ Particularly high increases in incidence have been observed among young minority women infected heterosexually.^10^

Over 500,000 cumulative deaths in the U.S. have occurred in persons with AIDS.^2^ Approximately 18,000 persons with AIDS died in 2002, compared to 19,000 in 1988. HIV remains the 7th leading cause of death in persons 15–24 years old and the 5th leading cause in persons 25–44 years old.^11^ The annual direct expenditure for the 335,000 HIV-infected Americans who received care in 1996 was estimated at $6.7 billion and $20,000 annually per patient.^12^ Approximately half of HIV-infected persons in the U.S. receive care from physicians without formal training in infectious diseases.^13^

## Healthcare Interventions

There remains no effective vaccine to prevent HIV infection and no cure for chronic infection. Interventions for HIV-infected patients include antiretroviral therapy, prophylaxis for opportunistic infections, immunizations, Papanicolaou testing, counseling to reduce high-risk behaviors, and routine monitoring and follow-up. HAART, defined as three or more antiretroviral agents used in combination (usually from at least two classes), is the standard of care for antiretroviral therapy.^14,^ ^15^ Of the interventions used to treat chronic HIV infection, HAART has the greatest impact on clinical outcomes, including survival. In a large U.S. observational study, for example, HAART was associated with a substantially lower relative risk for mortality (relative risk 0.15, 95% CI 0.12–0.17) compared to other interventions such as pneumococcal vaccination (relative risk 0.96, 95% CI 0.92–1.00), pneumocystis carinii pneumonia (PCP) prophylaxis (relative risk 0.79, 95% CI 0.70–0.89), and Mycobacterium avium complex (MAC) prophylaxis (RR 0.76, 95% CI 0.68–0.86).^16^ Accordingly, we emphasized evidence regarding the benefits and harms of HAART in this report.

Management of chronic HIV infections is a rapidly evolving area. Detailed and regularly updated guidelines for the U.S. population regarding appropriate timing of interventions and specifically recommended HAART regimens,^14,^ ^15^ chemoprophylaxis for opportunistic infections,^17^ immunizations,^17,^ ^18^ and counseling^19^ are available. In antitretroviral-naïve (persons who have not been exposed to antiretroviral therapy) patients, who have low progression rates after starting treatment, large long-term trials would be required to detect differences in clinical outcomes between HAART regimens.^20^ Because such trials are not yet available, guidelines regarding the specific choice of initial HAART therapy are primarily based on a combination of intermediate outcomes data and other considerations such as convenience, co-morbid conditions, potential for drug interactions, potential for the development of resistance, and side effect profile.^14^

## Natural History

HIV is an RNA retrovirus of the lentiretrovirus subfamily that was first isolated from a patient with AIDS in 1983.^21^ HIV is capable of particularly rapid replication and has a high propensity to mutate.^22^–^27^ There is significant genetic variation in HIV within individuals as well as populations. These characteristics explain some of the difficulties in developing effective vaccines and treatments.^28^–^30^

HIV is acquired through percutaneous exposure with infected bodily fluids such as blood, semen,^31^ and genital tract secretions.^32,^ ^33^ HIV-1 has also been recovered from other sites such as the anal-rectal canal^34^ and saliva.^35^ Factors facilitating sexual transmission include the presence of sexually transmitted diseases,^36^–^44^ high-risk sexual practices such as unprotected penile-anal intercourse,^45^–^49^ and high viral load in the infected partner.^50^–^52^ In the U.S., mean per-sex-act-probability of transmission has been estimated at 0.001 for unprotected penile-vaginal intercourse among heterosexual couples and at 0.005–0.03 for unprotected receptive anal intercourse among homosexual men.^53,^ ^54^ The risk of HIV transmission through unprotected orogenital sex appears to be very low.^55^ Male-to-female sexual transmission appears to occur with greater efficiency than female-to-male transmission.^48,^ ^56,^ ^57^ In injection drug users, factors associated with HIV infection include increased frequency or duration of injection, sharing needles, and backloading.^58^–^60^

The primary HIV infection syndrome usually develops 2 to 4 weeks following initial exposure to HIV.^61^ A clinical syndrome resembling infectious mononucleosis is often associated with acute infection.^62,^ ^63^ A high incidence of atypical and nonspecific symptoms make it difficult to recognize patients presenting with primary HIV infection syndrome.^64,^ ^65^

Very early after acute infection, rapid virus production results in plasma viremia of 106 to 107 HIV-1 copies/ml.^66^ Persons with acute HIV infection also have high semen concentrations of HIV-1, and may be particularly infectious.^67^ The viral load declines to a set point (which varies between individuals) as the host immune system responds, but continuous rapid virus production and clearance occurs at all stages of infection.^25,^ ^26,^ ^66,^ ^68^–^70^

Although a small proportion of untreated HIV-infected persons remain asymptomatic and show little evidence of progressive immune suppression after 10 or more years of infection,^71^–^76^ over 90% of untreated patients eventually develop AIDS.1 In the pre-HAART era, the median time from seroconversion to the development of AIDS was 7.7 to 11.0 years and median survival ranged from 7.5 to 12 years.^77,^ ^78^

The primary mechanism through which chronic HIV infection causes immune deficiency is through a decrease in the level and functioning of CD4+ T lymphocytes. On average, the CD4 count declines 50–75 cells/mm3 per year.^79^ Most patients with CD4 counts over 200 cells/mm3 are either asymptomatic or have mild disease.^80^ Patients with CD4 counts less than 200 cells/mm3 have advanced immunodeficiency and are at markedly increased risk for AIDS-related opportunistic infections and other AIDS-related complications.^80^–^88^ In the pre-HAART era, the chance of developing AIDS (using the 1987 case definition^89^) over 3 years was 86% in patients with a CD4 count less than 200 cells/mm3.^87^ A CD4 count of less than 200 cells/mm3 was added to the 1993 CDC case definition for AIDS.^1^

Another independent marker of poorer prognosis is increased HIV-1 viral load.^81,^ ^86^–^88,^ ^90^–^96^ Women may progress at lower viral loads than men.^97^–^100^ Older age is also a consistent independent risk factor for more rapid progression.^77,^ ^78,^ ^81,^ ^87,^ ^88,^ ^101,^ ^102^ Gender,^77,^ ^103^–^105^ transmission group,^77,^ ^88,^ ^103,^ ^106^ ethnicity or racial group,^77,^ ^107^ pregnancy status,^108^ use of alcohol or other drugs,^103,^ ^109^–^111^ socioeconomic status,^103,^ ^112^–^115^ and the presence of depression, decreased quality of life, or psychological stress^116^–^119^ have not been definitively established as consistent independent predictors of faster disease progression, particularly when adjusted for use of antiretroviral therapy or other measures of access to care.^103^ A host factor consistently associated with slow progression is the homozygous presence of the CCR5 delta32 genotype.^120^–^124^

## Prior Recommendations

The USPSTF published guidelines for HIV screening in 1996.^125^ At that time, the USPSTF recommended that clinicians should assess risk factors for HIV infection by obtaining a careful sexual history and inquiring about injection drug use in all patients, and recommended periodic screening for infection with HIV for all patients at increased risk of infection (“A” recommendation). The USPSTF found insufficient evidence to recommend for or against routine HIV screening in persons without identified risk factors.

The 2001 Centers for Disease Control and Prevention (CDC) recommendations are summarized in Table 1.^126^

Table 1 Current CDC Recommendations for Counseling and Testing for HIV Infection

Recommended screening | Examples
All clients in settings serving populations at increased behavioral or clinical HIV risk (regardless of setting HIV prevalence) | Adolescent or school-based health clinics with high rates of sexually transmitted diseases
| Clinics serving men who have sex with men
| Correctional facilities, prisons, juvenile detention centers
| Drug or alcohol prevention and treatment programs
| Freestanding HIV test sites
| Homeless shelters
| Outreach programs (e.g., syringe exchange programs)
| Sexually transmitted diseases clinics
| Tuberculosis clinics (only persons with confirmed or suspected tuberculosis and their contacts)
Individual clients in setting with <1% HIV prevalence who have:; - clinical signs or symptoms suggesting HIV infection; - diseases suggesting increased risk for HIV infection; - self-report HIV risks; - specifically request an HIV test | Fever or illness of unknown origin
| Opportunistic infection (including active tuberculosis disease) without known reason for immune suppression
| Another sexually transmitted disease or bloodborne infection
| Injection drug use with shared injection equipment (e.g., needles, syringes, cotton, water)
| Unprotected intercourse with someone suspected of being infected (partner injects drugs, diagnosed or treated for a sexually transmitted disease or hepatitis, has had multiple or anonymous sex partners, or has exchanged sex for drugs or money)
| Unprotected vaginal or anal intercourse with more than one sex partner
| Diagnosed or treated for a sexually transmitted disease, hepatitis, or tuberculosis
All clients in settings with a ≥1% HIV prevalence | Specific inpatient and outpatient settings with known high prevalence
Regardless of setting prevalence or behavioral or clinical risk; - all pregnant women; - all clients with possible acute occupational exposure; - all clients with known sexual or needle-sharing exposure to an HIV-infected person

Source: Centers for Disease Control and Prevention. Revised guidelines for HIV counseling, testing, and referral. Morbidity &Mortality Weekly Report -Recommendations & Reports. 2001;50(RR-19):1–57.^126^

## Scope of Evidence Synthesis

The analytic framework in Figure 1 indicates the strategy we used to evaluate screening for HIV infection in adolescents and adults. We considered screening to be testing for HIV infection in asymptomatic persons or those with mild nonspecific symptoms (such as fatigue) that are not predictive because they are so common. The key questions (Figure 2) guiding the literature review were developed in conjunction with liaisons from the USPSTF.

Figure 1. Screening for Human Immunodeficiency Virus—Analytic Framework for Asymptomatic Adolescents and Adults

Figure 2. Screening for Human Immunodeficiency Virus—Key Questions for Asymptomatic Adolescents and Adults

The analytic framework shows the target populations, interventions, and intermediate and health outcome measures we examined. Pregnant women are evaluated in an accompanying report. We excluded children (younger than 13 years old) because there is a low prevalence of HIV in this population (9.8 per 100,000 population) and most were infected vertically.^2^ We excluded other specific populations such as post-transplant patients,^127^ patients with known chronic viral hepatitis, ^128^–^132^ and hemodialysis patients.^133,^ ^134^ In these groups, treatment considerations,^135,^ ^136^ adverse effects from treatment,^137^–^141^ and natural history may differ from the general population of HIV-infected persons, and they are usually excluded from clinical trials. Patients with occupational exposures and blood donors were excluded because of consensus regarding testing for HIV infection in these situations.^142^ Studies of HIV-2 infection were excluded because it is very rare in the U.S. (less than 80 cases had been diagnosed as of 2000) and its natural history differs substantially from HIV-1 infection.^143,^ ^144^

Our review considered the standard screening strategy for HIV-1 infection to be an office-based venipuncture for anti-HIV enzyme linked immunosorbent assay (ELISA), followed by confirmatory Western blot for positive tests.^145,^ ^146^ We also considered rapid tests, home-based sampling, polymerase chain reaction, and tests using saliva or urine specimens. Viral load and CD4+ cell count testing was considered the standard work-up to determine the stage of infection and eligibility for interventions in infected patients.^14,^ ^15,^ ^17,^ ^18^

For treatment of chronic HIV infection, we evaluated recommended HAART regimens, prophylaxis for opportunistic infections, immunizations, Papanicolaou testing, counseling to reduce risky behaviors, and routine monitoring and follow-up. We excluded interventions not recommended for antiretroviral-naïve patients or not known to be effective. These include enfuvirtide,^147^–^149^ structured treatment interruptions,^150,^ ^151^ sequential initiation of antiretroviral drugs,^152^ induction-maintenance regimens,^153^–^159^ hydroxyurea,^160^ interleukin-2,^161^ acyclovir,^162^ and prophylaxis for candidiasis,^163^ histoplasmosis, coccidioidomycosis, herpes simplex virus infection, or cryptococcosis.^14,^ ^17^ We also did not consider resistance testing in antiretroviral-naïve patients a routine intervention. Although the presence of primary antiretroviral drug resistance is increasing,^164^–^169^ resistance testing has mainly been studied in patients who have already failed a regimen.^170^–^172^ In patients with untreated chronic HIV infection, current U.S. guidelines either do not recommend routine resistance testing^14^ or do not give firm recommendations.^173^

For outcomes, we were particularly interested in reviewing literature regarding the benefit of early interventions in asymptomatic, treatment-naïve patients. Clinical outcomes that we evaluated were mortality, AIDS-related opportunistic infections, spread of disease and quality of life or functional status. For counseling, we included rates of sexually transmitted diseases as clinical markers of high-risk behaviors. Intermediate outcomes were loss of detectable viremia, improvement in CD4 counts, and changes in risky behaviors. We also reviewed harms from screening, work-up and treatment. For harms from treatment, we focused on the long-term risk of cardiovascular complications and intolerable (causing discontinuation of the drug) side effects from HAART. Although interventions for chronic HIV infection, particularly HAART, are associated with many significant short-term side effects, many are tolerable or patients can be switched to effective alternative regimens. In addition, intention-to-treat analyses of clinical outcomes incorporate the effects of intolerable or serious side effects.^174^ Antiretroviral resistance also was not included as a separate outcome as its effects are seen in other intermediate (CD4 count, viral load) and clinical outcomes.