# Appendix E. Statistical Methods Used for Outcomes Table (Table 13)

## Relative risk for clinical progression or death on HAART compared to no treatment

Because there are no clinical trials directly evaluating the relative risk for clinical progression or death associated with HAART (antiretroviral therapy with three drugs) compared to no treatment in HIV-infected persons, we calculated this relative risk indirectly from data provided in a systematic review of clinical trials of one-drug therapy (monotherapy) versus placebo, two- (dual therapy) versus one-drug therapy and three- (triple therapy) versus two-drug therapy in antiretroviral-naïve persons.^1^ For this calculation, if P _N_, P _M_, P _D_, P _T_ denote the proportion of patients with clinical progression or death on no treatment (placebo), one-drug therapy, two-drug therapy and three-drug therapy, then the relative risk for clinical progression or death on three-drug therapy vs. placebo (RR _TN_) is given by:

To calculate the (1 - α)% CI for RR _TN_, it is usual to use the natural log scale:

log(RR _TN_) = log(RR _MN_) + log(RR _DM_) + log(RR _TD_) (2)

and the variance of log relative risk is given as:

by assuming independence among log(RR _MN_), log(RR _DM_) and log(RR _TD_). Since log(RR _TN_) is approximately normally distributed, the (1 - α)% CI for RR _TN_ are

Jordan et al reported the rates for clinical progression or death from clinical trials of one-drug therapy vs. placebo (15 studies), two- vs. one-drug therapy (16 studies) and three- versus two-drug therapy (9 studies).^1^ In our analysis, estimates of RR _MN_ and var(log(RR _MN_)) were obtained from a meta-analysis of the 15 one-drug therapy versus placebo trials. Similarly, estimates of RR _DM_ and var(log(RR _DM_)) were obtained from a meta-analysis of the 16 two- versus one-drug therapy trials; and RR _TD_ and var(log(RR _TD_)) from a meta-analysis of the 9 three- versus two-drug therapy studies. We assumed independence between log(RR _MN_), log(RR _DM_) and log(RR _TD_) because each value was estimated from different trials. Overall estimates of RR _TN_ and its corresponding 95% CI was calculated by plugging these estimates into formulas (1) – (4). For each meta-analysis, tests for heterogeneity indicated significant variation among studies, so we used a random effects model to combine the relative risk from each model. Estimates of RR _TN_ and its corresponding 95% CI from a fixed effect model, however, was similar to those from a random effects model. Jordan et al used a fixed effect approach to estimate odd ratio of monotherapy vs. placebo, double therapy vs. monotherapy and triple therapy vs. double therapy.^1^

## Rates of cardiovascular complications

The background rate (cases per three person-years) and relative risk for myocardial infarction and cardio- and cerebrovascular events (myocardial infarction, stroke, or invasive cardiovascular procedures) associated with combination antiretroviral therapy after 2–4 years compared to no exposure were calculated based on raw data from the Data Collection on Adverse Events of Anti-HIV Drugs (DAD) Study (Figure 1, using outcomes for no antiretroviral treatment and combined outcomes for 2–3 and 3–4 years of exposure) using standard statistical methods.^2,^ ^3^

## Calculation of numbers needed to screen (NNS) and numbers needed to treat (NNT)

Calculations of NNS and NNT were based on estimates from different sources in the literature (Table 13). The indicated range of estimates and variation associated with estimates were incorporated in the calculations and reflected by the ranges in the calculated NNS and NNT. Variation associated with the estimates was estimated using Monte Carlo simulations. The distributions of the estimates used in the simulations were either the underlying distribution on which the calculation of 95% confidence interval (CI) was based on, or one that best approximated the point estimate and CI. For example, if the estimate was a rate or proportion, the logit of the rate or proportion was sampled assuming an approximately normal distribution, and then transformed back to its original scale. For relative risk, we assumed that the log of relative risk was approximately normally distributed. The point estimates and 95% CI of NNS and NNT were based on 1,000,000 simulations.

## References

1 Jordan R, Gold L, Cummins C, Hyde C. Systematic review and meta-analysis of evidence for increasing numbers of drugs in antiretroviral combination therapy. BMJ. 2002;324:1-10. [pmid: 11777781]. [pmcid: 1121932].
2 Friis-Moller N, Sabin CA, Weber R, et al. Combination antiretroviral therapy and the risk of myocardial infarction. New England Journal of Medicine. 2003;349(21):1993-2003. [pmid: 14627784].
3 Writing Committee of the DAD Study Group. Cardio- and cerebrovascular events in HIV-infected persons. AIDS. 2004;18:1811-1817. [pmid: 15316342].