# References

1 Jemal A, Murray T, Samuels A, Ghafoor A, Ward E, Thun MJ. Cancer statistics, 2003. CA Cancer J Clin. 2003;53:5-26. [pmid: 12568441].
2 Gail MH, Brinton LA, Byar DP, et al. Projecting individualized probabilities of developing breast cancer for white females who are being examined annually. J Natl Cancer Inst. 1989;81(24):1879-1886. [pmid: 2593165].
3 Colditz GA, Willett WC, Hunter DJ, et al. Family history, age, and risk of breast cancer. Prospective data from the Nurses' Health Study. JAMA. 1993;270(3):338-343. [pmid: 8123079].
4 American Cancer Society: Cancer Facts and Figures 2004. Atlanta, GA: American Cancer Society, 2004. Available at: http://www.cancer.org/downloads/STT/CAFF_finalPWSecured.pdf. Accessed April 30, 2004.
5 Yang Q, Khoury MJ, Rodriguez C, Calle EE, Tatham LM, Flanders WD. Family history score as a predictor of breast cancer mortality: prospective data from the Cancer Prevention Study II, United States, 1982-1991. Am J Epidemiol. 1998;147(7):652-659. [pmid: 9554604].
6 Slattery ML, Kerber RA. A comprehensive evaluation of family history and breast cancer risk. The Utah Population Database. JAMA. 1993;270(13):1563-1568. [pmid: 8371466].
7 Johnson N, Lancaster T, Fuller A. The prevalence of a family history of cancer in general practice. Fam Pract. 1995;12(3):287-289. [pmid: 8536831].
8 Pharoah PD, Day NE, Duffy S, Easton DF, Ponder BA. Family history and the risk of breast cancer: a systematic review and meta-analysis. Int J Cancer. 1997;71(5):800-809. [pmid: 9180149].
9 Miki Y, Swensen J, Shattuck-Eidens D, et al. A Strong candidate for the breast and ovarian cancer susceptibility gene BRCA1. Science. 1994;266(5182):66-71. [pmid: 7545954].
10 Wooster R, Bignell G, Lancaster J. Identification of the breast cancer susceptibility gene BRCA2. Nature. 1995;378:789-792. [pmid: 8524414].
11 Struewing JP, Hartge P, Wacholder S, et al. The risk of cancer associated with specific mutations of BRCA1 and BRCA2 among Ashkenazi Jews. N Engl J Med. 1997;336(20):1401-1408. [pmid: 9145676].
12 Roa BB, Boyd AA, Volcik K, Richards CS. Ashkenazi Jewish population frequencies for common mutations in BRCA1 and BRCA2. Nat Genet. 1996;14:185-187. [pmid: 8841191].
13 Neuhausen S, Gilewski T, Norton L, et al. Recurrent BRCA2 6174delT mutations in Ashkenazi Jewish women affected by breast cancer. Nature Genetics. 1996;13(1):126-128. [pmid: 8673092].
14 Peelen T, van Vliet M, Petrij-Bosch A, et al. A high proportion of novel mutations in BRCA1 with strong founder effects among Dutch and Belgian hereditary breast and ovarian cancer families. Am J Hum Genet. 1997;60(5):1041-1049. [pmid: 9150151]. [pmcid: 1712432].
15 Thorlacius S, Olafsdottir G, Tryggvadottir L, et al. A single BRCA2 mutation in male and female breast cancer families from Iceland with varied cancer phenotypes. Nat Genet. 1996;13(1):117-119. [pmid: 8673089].
16 Arason A, Jonasdottir A, Barkardottir RB, et al. A population study of mutations and LOH at breast cancer gene loci in tumours from sister pairs: two recurrent mutations seem to account for all BRCA1/BRCA2 linked breast cancer in Iceland. J Med Genet. 1998;35(6):446-449. [pmid: 9643283]. [pmcid: 1051336].
17 Einbeigi Z, Bergman A, Kindblom LG, et al. A founder mutation of the BRCA1 gene in Western Sweden associated with a high incidence of breast and ovarian cancer. Eur J Cancer. 2001;37(15):1904-1909. [pmid: 11576847].
18 Wooster R, Weber BL. Breast and ovarian cancer. N Engl J Med. 2003;348(23):2339-2347. [pmid: 12788999].
19 Lindor NM, Greene MH. Mayo Familial Cancer Program. The concise handbook of family cancer syndromes. J Natl Cancer Inst. 1998;90(14):1039-1071. [pmid: 9672254].
20 Liede A, Karlan BY, Narod SA. Cancer risks for male carriers of germline mutations in BRCA1 or BRCA2: a review of the literature. J Clin Oncol. 2004;22(4):735-742. [pmid: 14966099].
21 Brose MS, Rebbeck TR, Calzone KA, Stopfer JE, Nathanson KL, Weber BL. Cancer risk estimates for BRCA1 mutation carriers identified in a risk evaluation program. J Natl Cancer Inst. 2002;94(18):1365-1372. [pmid: 12237282].
22 Thompson D, Easton DF. Cancer incidence in BRCA1 mutation carriers. J Natl Cancer Inst. 2002;94(18):1358-1365. [pmid: 12237281].
23 Easton D, Ford D, Bishop DT. The breast cancer linkage consortium. Breast and ovarian cancer incidence in BRCA1-mutation carriers. Am J Hum Genet. 1995;56(265–271).
24 Ford D, Easton D. The genetics of breast and ovarian cancer. Br J Cancer. 1995;72(805–812).
25 Ford D, Easton D, Bishop DT, Narod SA, Goldgar DE. The breast cancer linkage consortium. Risks of cancer in BRCA1-mutation carriers. Lancet. 1994;343:692-695. [pmid: 7907678].
26 Easton D, Bishop DT, Ford D, Crockford GP. The breast cancer linkage consortium. Genetic linkage analysis in familial breast and ovarian cancer. Am J Med Genet. 1993;52(678–701).
27 Anglian Breast Cancer Study Group. Prevalence and penetrance of BRCA1 and BRCA2 mutations in a population-based series of breast cancer cases. Br J Cancer. 2000;83(10):1301-1308. [pmid: 11044354].
28 Antoniou AC, Pharoah PD, McMullan G, et al. A comprehensive model for familial breast cancer incorporating BRCA1, BRCA2 and other genes. Br J Cancer. 2002;86(1):76-83. [pmid: 11857015].
29 Peto J, Collins N, Barfoot R, et al. Prevalence of BRCA1 and BRCA2 gene mutations in patients with early-onset breast cancer. J Natl Cancer Inst. 1999;91(11):943-949. [pmid: 10359546].
30 Antoniou AC, Gayther SA, Stratton JF, Ponder BA, Easton DF. Risk models for familial ovarian and breast cancer. Genet Epidemiol. 2000;18(2):173-190. [pmid: 10642429].
31 American College of Medical Genetics Professional Practice and Guidelines Committee. Genetic susceptibility to breast and ovarian cancer: assessment, counseling, and testing guidelines executive summary. October 1999. Available at: http://www.health.state.ny.us/nysdoh/cancer/obcancer/contents.htm. Accessed November 26, 2003.
32 Statement of clinical oncology: Genetic testing for cancer susceptibility, adopted on February 20, 1996. J Clin Oncol. 1996;14(5):1730–1736.
33 Frank TS, Deffenbaugh AM, Reid JE, et al. Clinical characteristics of individuals with germline mutations in BRCA1 and BRCA2: analysis of 10,000 individuals. J Clin Oncol. 2002;20(6):1480-1490. [pmid: 11896095].
34 Srivastava A, McKinnon W, Wood ME. Risk of breast and ovarian cancer in women with strong family histories. Oncology (Huntington). 2001;15(7):889-902. discussion 902, 905–887, 911–813.
35 Shattuck-Eidens D, Oliphant A, McClure M, et al. BRCA1 sequence analysis in women at high risk for susceptibility mutations. Risk factor analysis and implications for genetic testing. JAMA. 1997;278(15):1242-1250. [pmid: 9333265].
36 Couch FJ, DeShano ML, Blackwood MA, et al. BRCA1 mutations in women attending clinics that evaluate the risk of breast cancer. N Engl J Med. 1997;336(20):1409-1415. [pmid: 9145677].
37 Ad Hoc Committee on Genetic Counseling of the American Society of Human Genetics. Am J Hum Genet. 1975;27:240–242.
38 Bowen DJ, Burke W, McTiernan A, Yasui Y, Anderson MR. Breast cancer risk counseling improves women's functioning. Patient Educ Couns. 2004;53:79-86. [pmid: 15062908].
39 Bowen DJ, Burke W, Yasui Y, McTiernan A, McLeran D. Effects of risk counseling on interest in breast cancer genetic testing for lower risk women. Genet Med. 2002;4(5):359-365. [pmid: 12394349].
40 Burke W, Culver JO, Bowen D, et al. Genetic counseling for women with an intermediate family history of breast cancer. Am J Med Genet. 2000;90(5):361-368. [pmid: 10706356].
41 Cull A, Miller H, Porterfield T, et al. The use of videotaped information in cancer genetic counselling: a randomized evaluation study. Br J Cancer. 1998;77(5):830-837. [pmid: 9514066].
42 Lerman C, Hughes C, Benkendorf JL, et al. Racial differences in testing motivation and psychological distress following pretest education for BRCA1 gene testing. Cancer Epidemiol Biomarkers Prev. 1999;8(4 Pt 2):361-367. [pmid: 10207641].
43 Lerman C, et al. A randomized trial of breast cancer risk counseling: interacting effects of counseling, educational level, and coping style. Health Psychology. 1996;15(2):75-83. [pmid: 8681923].
44 Lerman C, Lustbader E, Rimer B, et al. Effects of individualized breast cancer risk counseling: a randomized trial. J Natl Cancer Inst. 1995;87(4):286-292. [pmid: 7707420].
45 Rahman N, Stratton MR. The genetics of breast cancer susceptibility. Annu Rev Genet. 1998;32:95-121. [pmid: 9928476].
46 Myriad Genetic Laboratories, Inc. Available at: http://www.myriadtests.com/home.htm. Accessed April 30, 2004.
47 Unger MA, Nathanson KL, Calzone K, et al. Screening for genomic rearrangements in families with breast and ovarian cancer identifies BRCA1 mutations previously missed by conformation-sensitive gel electrophoresis or sequencing. Am J Hum Genet. 2000;67(4):841-850. [pmid: 10978226]. [pmcid: 1287889].
48 U.S. Preventive Services Task Force Recommendations and Rationale: Screening for Breast Cancer. Available at: ahrq.gov/clinic/uspstf/uspsbrca.htm. Ann Intern Med. 2002;137:344–346.
49 Burke W, Daly M, Garber J, et al. Recommendations for follow-up care of individuals with an inherited predisposition to cancer. II. BRCA1 and BRCA2. Cancer Genetics Studies Consortium. JAMA. 1997;277(12):997-1003. [pmid: 9091675].
50 Kuhl CK, Schmutzler RK, Leutner CC, et al. Breast MR imaging screening in 192 women proved or suspected to be carriers of a breast cancer susceptibility gene: preliminary results. Radiology. 2000;215(1):267-279. [pmid: 10751498].
51 Morris EA, Liberman L, Ballon DJ, et al. MRI of occult breast carcinoma in a high-risk population. AJR Am J Roentgenol. 2003;181(3):619-626. [pmid: 12933450].
52 Kerlikowske K, Carney PA, Geller BM, et al. Performance of screening mammography among women with and without a first-degree relative with breast cancer. Ann Intern Med. 2000;133:855-863. [pmid: 11103055].
53 Kerlikowske K, Grady D, Barclay J, Sickles EA, Ernster V. Effects of age, breast density, and family history on the sensitivity of first screening mammography. JAMA. 1996;276:33-38. [pmid: 8667536].
54 Chang J, Yang WT, Choo HF. Mammography in Asian patients with BRCA1 mutations. Lancet. 1999;353(9169):2070-2071. [pmid: 10376643].
55 Warner E, Plewes DB, Hill KA, et al. Surveillance of BRCA1 and BRCA2 mutation carriers with magnetic resonance imaging, ultrasound, mammography, and clinical breast examination. JAMA. 2004;292(11):1317-1325. [pmid: 15367553].
56 U.S. Preventive Services Task Force Recommendations and Rationale, Screening for Ovarian Cancer. 2004. Available at: http://www.ahrq.gov/clinic/3rduspstf/ovariancan/ovcanrs.htm. Accessed October 19, 2004.
57 NIH Consensus Conference. Ovarian cancer: screening, treatment, and follow-up. NIH Consensus Development Panel on Ovarian Cancer. JAMA. 1995;273(6):491–497.
58 Dhingra K. Antiestrogens—tamoxifen, SERMs and beyond. Invest New Drugs. 1999;17(3):285-311. [pmid: 10665480].
59 IBIS Investigators. First results from the International Breast Cancer Intervention Study (IBIS-I): a randomised prevention trial.[comment]. Lancet. 2002;360(9336):817-824. [pmid: 12243915].
60 Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. 1998;90(18):1371-1388. [pmid: 9747868].
61 Powles T, Eeles R, Ashley S, et al. Interim analysis of the incidence of breast cancer in the Royal Marsden Hospital tamoxifen randomised chemoprevention trial. Lancet. 1998;352(9122):98-101. [pmid: 9672274].
62 Veronesi U, Maisonneuve P, Costa A, et al. Prevention of breast cancer with tamoxifen: preliminary findings from the Italian randomised trial among hysterectomised women. Lancet. 1998;352(9122):93-97. [pmid: 9672273].
63 Cuzick J, Powles T, Veronesi U, et al. Overview of the main outcomes in breast-cancer prevention trials. Lancet. 2003;361(9354):296-300. [pmid: 12559863].
64 Cummings SR, Eckert S, Krueger KA, et al. The effect of raloxifene on risk of breast cancer in postmenopausal women: results from the MORE randomized trial. JAMA. 1999;281(23):2189-2197. [pmid: 10376571].
65 Phase III randomized study of tamoxifen and raloxifene (STAR) for the prevention of breast cancer. 01-21-2004. Available at: http://www.cancer.gov/clinicaltrials/view_clinicaltrials.aspx?version=healthprofessional&cdrid=67081&protocolsearchid=884140. Accessed April 20, 2004.
66 Barrett-Connor E, Wenger NK, Grady D, et al. Hormone and nonhormone therapy for the maintenance of postmenopausal health: the need for randomized controlled trials of estrogen and raloxifene. J Womens Health. 1998;7(7):839-847. [pmid: 9785310].
67 Braithwaite RS, Chlebowski RT, Lau J, George S, Hess R, Col NF. Meta-analysis of vascular and neoplastic events associated with tamoxifen. J Gen Intern Med. 2003;18(11):937-947. [pmid: 14687281]. [pmcid: 1494944].
68 Curtis MG. Comparative tolerability of first-generation selective estrogen receptor modulators in breast cancer treatment and prevention. Drug Safety. 2001;24(14):1039-1053. [pmid: 11735660].
69 U.S. Preventive Services Task Force Recommendations and Rationale: Chemoprevention of Breast Cancer. Available at: ahrq.gov/clinic/uspstf/uspsbrpv.htm. Ann Intern Med. 2002;137(1):56–58.
70 Meijers-Heijboer H, van Geel B, van Putten WL, et al. Breast cancer after prophylactic bilateral mastectomy in women with a BRCA1 or BRCA2 mutation. N Engl J Med. 2001;345(3):159-164. [pmid: 11463009].
71 Rebbeck TR, Friebel T, Lynch HT, et al. Bilateral prophylactic mastectomy reduces breast cancer risk in BRCA1 and BRCA2 mutation carriers: the PROSE Study Group. J Clin Oncol. 2004;22(6):1055-1062. [pmid: 14981104].
72 Rebbeck TR, Levin AM, Eisen A, et al. Breast cancer risk after bilateral prophylactic oophorectomy in BRCA1 mutation carriers. J Natl Cancer Inst. 1999;91(17):1475-1479. [pmid: 10469748].
73 Rebbeck TR. Prophylactic oophorectomy in BRCA1 and BRCA2 mutation carriers. Eur J Cancer. 2002;38(Suppl 6):S15-17. [pmid: 12409058].
74 Kauff ND, Satagopan JM, Robson ME, et al. Risk-reducing salpingo-oophorectomy in women with a BRCA1 or BRCA2 mutation. N Engl J Med. 2002;346(21):1609-1615. [pmid: 12023992].
75 Woods JE. Breast reconstruction: current state of the art. Mayo Clinic Proceedings. 1986;61:579-585. [pmid: 3713262].
76 Wapnir IL, Rabinowitz B, Greco RS. A reappraisal of prophylactic mastectomy. Surg Gynecol Obstet. 1990;171(2):171-184. [pmid: 2200150].
77 Goodnight JE, Quagliana JM, Morton DL. Failure of subcutaneous mastectomy to prevent the development of breast cancer. J Surg Oncol. 1984;26:198-201. [pmid: 6330460].
78 Pennisi VR, Capozzi A. Subcutaneous mastectomy data. Aesthetic Plast Surg. 1989;13:15-21. [pmid: 2728994].
79 Paley PJ, Swisher EM, Garcia RL, et al. Occult cancer of the fallopian tube in BRCA-1 germline mutation carriers at prophylactic oophorectomy: a case for recommending hysterectomy at surgical prophylaxis. Gynecol Oncol. 2001;80:176-180. [pmid: 11161856].
80 Aziz S, Kuperstein G, Rosen B, et al. A genetic epidemiological study of carcinoma of the fallopian tube. Gynecol Oncol. 2001;80(3):341-345. [pmid: 11263928].
81 Tobacman JK, Greene MH, Tucker MA, Costa J, Kase R, Fraumeni JF Jr. Intra-abdominal carcinomatosis after prophylactic oophorectomy in ovarian-cancer-prone families. Lancet. 1982;2(8302):795-797. [pmid: 6126666].
82 Piver MS, Jishi MF, Tsukada Y, Nava G. Primary peritoneal carcinoma after prophylactic oophorectomy in women with a family history of ovarian cancer. A report of the Gilda Radner Familial Ovarian Cancer Registry. Cancer. 1993;71(9):2751-2755. [pmid: 8467455].
83 Bandera CA, Muto MG, Schorge JO, Berkowitz RS, Rubin SC, Mok SC. BRCA1 gene mutations in women with papillary serous carcinoma of the peritoneum. Obstet Gynecol. 1998;92:596-600. [pmid: 9764635].
84 Slavin RE. Best practice synthesis: an alternative to meta-analytic and traditional reviews. Education Research. 1986;15:5-11.
85 Collaborative Group on Hormonal Factors in Breast Cancer. Familial breast cancer: collaborative reanalysis of individual data from 52 epidemiological studies including 58,209 women with breast cancer and 101,986 women without the disease. Lancet. 2001;358(9291):1389-1399. [pmid: 11705483].
86 Hartge P, Struewing JP, Wacholder S, Brody LC, Tucker MA. The prevalence of common BRCA1 and BRCA2 mutations among Ashkenazi Jews. Am J Hum Genet. 1999;64(4):963-970. [pmid: 10090881]. [pmcid: 1377820].
87 Cancer Genetics Network. Available at: http://epi.grants.center.gov/CGN/. Accessed March 20, 2005.
88 DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled Clinical Trials. 1986;7:177-188. [pmid: 3802833].
89 Bowen D, Christensen C, Powers D, Graves D, Anderson C. Effects of counseling and ethnic identity on perceived risk and cancer worry in African American women. Journal of Clinical Psychology in Medical Settings. 1998;5:365-379.
90 Stratton JF, Pharoah P, Smith SK, Easton D, Ponder BA. A systematic review and meta-analysis of family history and risk of ovarian cancer. Br J Obstet Gynaecol. 1998;105(5):493-499. [pmid: 9637117].
91 Murff HJ, Spigel DR, Syngal S. Does this patient have a family history of cancer? An evidence-based analysis of the accuracy of family cancer history. JAMA. 2004;292(12):1480-1489. [pmid: 15383520].
92 Kerber RA, Slattery ML. Comparison of self-reported and database-linked family history of cancer data in a case-control study. Am J Epidemiol. 1997;146(3):244-248. [pmid: 9247008].
93 Domchek SM, Eisen A, Calzone K, Stopfer J, Blackwood A, Weber BL. Application of breast cancer risk prediction models in clinical practice. J Clin Oncol. 2003;21(4):593-601. [pmid: 12586794].
94 Frank TS, Manley SA, Olopade OI, et al. Sequence analysis of BRCA1 and BRCA2: correlation of mutations with family history and ovarian cancer risk. J Clin Oncol. 1998;16(7):2417-2425. [pmid: 9667259].
95 Blackwood MA, Yang H, Margolin A, et al. Predicted probability of breast cancer susceptibility gene mutations. Breast Cancer Res Treat. 2001;69:223.
96 Berry DA, Parmigiani G, Sanchez J, Schildkraut J, Winer E. Probability of carrying a mutation of breast-ovarian cancer gene BRCA1 based on family history. J Natl Cancer Inst. 1997;89(3):227-238. [pmid: 9017003].
97 Berry DA, Iversen ES Jr, Gudbjartsson DF, et al. BRCAPRO validation, sensitivity of genetic testing of BRCA1/BRCA2, and prevalence of other breast cancer susceptibility genes. J Clin Oncol. 2002;20(11):2701-2712. [pmid: 12039933].
98 Parmigiani G, Berry D, Aguilar O. Determining carrier probabilities for breast cancer-susceptibility genes BRCA1 and BRCA2. Am J Hum Genet. 1998;62(1):145-158. [pmid: 9443863]. [pmcid: 1376797].
99 Euhus DM, Smith KC, Robinson L, et al. Pretest prediction of BRCA1 or BRCA2 mutation by risk counselors and the computer model BRCAPRO. J Natl Cancer Inst. 2002;94(11):844-851. [pmid: 12048272].
100 Euhus D. Risk modeling in breast cancer. Breast Journal. 2004;10(Suppl 1):S10-12. [pmid: 14984482].
101 CancerGene with BRCAPRO. The University of Texas Southwestern Medical Center at Dallas. Available at: www3.utsouthwestern.edu/cancergene. Accessed April 30, 2004.
102 Cyrillic-Software. Available at: www.cyrillicsoftware.com. Accessed April 30, 2004.
103 Tyrer J, Duffy SW, Cuzick J. A breast cancer prediction model incorporating familial and personal risk factors. Statistics in Medicine. 2004;23:1111-1130. [pmid: 15057881].
104 Gilpin CA, Carson N, Hunter AG. A preliminary validation of a family history assessment form to select women at risk for breast or ovarian cancer for referral to a genetics center. Clinical Genetics. 2000;58(4):299-308. [pmid: 11076055].
105 Claus EB, Risch H, Thompson WD. Genetic analysis of breast cancer in the cancer and steroid hormone study. Am J Hum Genet. 1991;48:232-242. [pmid: 1990835]. [pmcid: 1683001].
106 Evans DGR, Eccles DM, Rahman N, et al. A new scoring system for the chances of identifying a BRCA 1/2 mutation outperforms existing models including BRCAPRO. J Med Genet. 2004;41:474-480. [pmid: 15173236]. [pmcid: 1735807].
107 Emery J, Walton R, Coulson A, Glasspool D, Ziebland S, Fox J. Computer support for recording and interpreting family histories of breast and ovarian cancer in primary care (RAGs): qualitative evaluation with simulated patients. BMJ. 1999;319(7201):32-36. [pmid: 10390458]. [pmcid: 28153].
108 Coulson AS, Glasspool DW, Fox J, Emery J. RAGs: A novel approach to computerized genetic risk assessment and decision support from pedigrees. Methods Inf Med. 2001;40(4):315-322. [pmid: 11552344].
109 Emery J, Walton R, Murphy M, et al. Computer support for interpreting family histories of breast and ovarian cancer in primary care: comparative study with simulated cases. BMJ. 2000;321(7252):28-32. [pmid: 10875832]. [pmcid: 27423].
110 Mouchawar J, Valentine Goins K, Somkin C, et al. Guidelines for breast and ovarian cancer genetic counseling referral: adoption and implementation in HMOs. Genet Med. 2003;5(6):444-450. [pmid: 14614396].
111 de Silva D, Gilbert F, Needham G, Deans H, Turnpenny P, Haites N. Identification of women at high genetic risk of breast cancer through the National Health Service Breast Screening Programme (NHSBSP). J Med Genet. 1995;32(11):862-866. [pmid: 8592328]. [pmcid: 1051736].
112 National Comprehensive Cancer Network. Breast Cancer Risk Reduction: Clinical Practice Guidelines in Oncology; 2004.
113 Genetic susceptibility to breast and ovarian cancer: assessment, counseling and testing guidelines: New York State Department of Health; 2004. Available at: www.health.state.ny.us/nysdoh/cancer/obcancer/pp6–12 (http://www.health.state.ny.us/nysdoh/cancer/obcancer/pp6-12). Accessed March18, 2004.
114 National Breast Cancer Centre (NBCC). Advice About Familial Aspects of Breast Cancer and Ovarian Cancer - A Guide for Health Professionals. Sydney, Australia: NBCC; 2000.
115 de Bock GH, Vliet Vlieland TP, Hageman GC, Oosterwijk JC, Springer MP, Kievit J. The assessment of genetic risk of breast cancer: a set of GP guidelines. Fam Pract. 1999;16(1):71-77. [pmid: 10321400].
116 Pichert G, Stahel RA. Organizing cancer genetics programs: the Swiss model. J Clin Oncol. 2000;18(21 Suppl):65S-69S. [pmid: 11060330].
117 Hampel H, Sweet K, Westman JA, Offit K, Eng C. Referral for cancer genetics consultation: a review and compilation of risk assessment criteria. J Med Genet. 2004;41:81-91. [pmid: 14757853]. [pmcid: 1735676].
118 Lobb E, Butow P, Meiser B, et al. The use of audiotapes in consultations with women from high risk breast cancer families: a randomised trial. J Med Genet. 2002;39(9):697-703. [pmid: 12205117]. [pmcid: 1735239].
119 Watson M, Duvivier V, Wade Walsh M, et al. Family history of breast cancer: what do women understand and recall about their genetic risk?. J Med Genet. 1998;35(9):731-738. [pmid: 9733031]. [pmcid: 1051425].
120 Green MJ, Peterson SK, Baker MW, et al. Effect of a computer-based decision aid on knowledge, perceptions, and intentions about genetic testing for breast cancer susceptibility: a randomized controlled trial. JAMA. 2004;292(4):442-452. [pmid: 15280342]. [pmcid: 1237120].
121 Meiser B, Halliday JL. What is the impact of genetic counselling in women at increased risk of developing hereditary breast cancer? A meta-analytic review. Social Science & Medicine. 2002;54(10):1463-1470. [pmid: 12061481].
122 Lerman C, Trock B, Rimer BK, Jepson C, Brody D, Boyce A. A psychological side effect of breast cancer screening. Health Psychology. 1991;10:259-267. [pmid: 1915212].
123 Centers for Disease Control Prevention. Genetic testing for breast and ovarian cancer susceptibility: evaluating direct-to-consumer marketing—Atlanta, Denver, Raleigh-Durham, and Seattle, 2003. MMWR Morbidity & Mortality Weekly Report. 2004;53(27):603-606. [pmid: 15254451].
124 Eng C, Brody LC, Wagner TM, et al. Interpreting epidemiological research: blinded comparison of methods used to estimate the prevalence of inherited mutations in BRCA1. J Med Genet. 2001;38(12):824-833. [pmid: 11748305]. [pmcid: 1734796].
125 Fodor FH, Weston A, Bleiweiss IJ, et al. Frequency and carrier risk associated with common BRCA1 and BRCA2 mutations in Ashkenazi Jewish breast cancer patients. Am J Hum Genet. 1998;63(1):45-51. [pmid: 9634504]. [pmcid: 1377227].
126 Struewing JP, Abeliovich D, Peretz T, et al. The carrier frequency of the BRCA1 185delAG mutation is approximately 1 percent in Ashkenazi Jewish individuals.[erratum appears in Nat Genet 1996 Jan;12(1):110]. Nat Genet. 1995;11(2):198-200. [pmid: 7550349].
127 Modan B, Hartge P, Hirsh-Yechezkel G, et al. Parity, oral contraceptives, and the risk of ovarian cancer among carriers and noncarriers of a BRCA1 or BRCA2 mutation. N Engl J Med. 2001;345(4):235-240. [pmid: 11474660].
128 Oddoux C, Struewing JP, Clayton CM, et al. The carrier frequency of the BRCA2 6174delT mutation among Ashkenazi Jewish individuals is approximately 1%. Nat Genet. 1996;14(2):188-190. [pmid: 8841192].
129 Liede A, Karlan BY, Baldwin RL, Platt LD, Kuperstein G, Narod SA. Cancer incidence in a population of Jewish women at risk of ovarian cancer. J Clin Oncol. 2002;20(6):1570-1577. [pmid: 11896106].
130 Antoniou A, Pharoah PD, Narod S, et al. Average risks of breast and ovarian cancer associated with BRCA1 or BRCA2 mutations detected in case series unselected for family history: a combined analysis of 22 studies. Am J Hum Genet. 2003;72(5):1117-1130. [pmid: 12677558]. [pmcid: 1180265].
131 Ford D, Easton DF, Stratton M, et al. Genetic heterogeneity and penetrance analysis of the BRCA1 and BRCA2 genes in breast cancer families. Am J Hum Genet. 1998;62(3):676-689. [pmid: 9497246]. [pmcid: 1376944].
132 Hopper JL, Southey MC, Dite GS, et al. Population-based estimate of the average age-specific cumulative risk of breast cancer for a defined set of protein-truncating mutations in BRCA1 and BRCA2. Australian Breast Cancer Family Study. Cancer Epidemiol Biomarkers Prev. 1999;8(9):741-747. [pmid: 10498392].
133 Risch HA, McLaughlin JR, Cole DE, et al. Prevalence and penetrance of germline BRCA1 and BRCA2 mutations in a population series of 649 women with ovarian cancer. Am J HumGenet. 2001;68(3):700-710. [pmid: 11179017]. [pmcid: 1274482].
134 King MC, Marks JH, Mandell JB. Breast and ovarian cancer risks due to inherited mutations in BRCA1 and BRCA2. Science. 2003;302(5645):643-646. [pmid: 14576434].
135 Moslehi R, Chu W, Karlan B, et al. BRCA1 and BRCA2 mutation analysis of 208 Ashkenazi Jewish women with ovarian cancer. Am J Hum Genet. 2000;66(4):1259-1272. [pmid: 10739756]. [pmcid: 1288193].
136 Satagopan JM, Boyd J, Kauff ND, et al. Ovarian cancer risk in Ashkenazi Jewish carriers of BRCA1 and BRCA2 mutations. Clinical Cancer Research. 2002;8(12):3776-3781. [pmid: 12473589].
137 Satagopan JM, Offit K, Foulkes W, et al. The lifetime risks of breast cancer in Ashkenazi Jewish carriers of BRCA1 and BRCA2 mutations. Cancer Epidemiol Biomarkers Prev. 2001;10(5):467-473. [pmid: 11352856].
138 Warner E, Foulkes W, Goodwin P, et al. Prevalence and penetrance of BRCA1 and BRCA2 gene mutations in unselected Ashkenazi Jewish women with breast cancer. J Natl Cancer Inst. 1999;91(14):1241-1247. [pmid: 10413426].
139 Gayther SA, Mangion J, Russell P, et al. Variation of risks of breast and ovarian cancer associated with different germline mutations of the BRCA2 gene. Nat Genet. 1997;15(1):103-105. [pmid: 8988179].
140 Begg CB. On the use of familial aggregation in population-based case probands for calculating penetrance. J Natl Cancer Inst. 2002;94(16):1221-1226. [pmid: 12189225].
141 Eccles DM, Englefield P, Soulby MA, Campbell IG. BRCA1 mutations in southern England. Br J Cancer. 1998;77(12):2199-2203. [pmid: 9649133].
142 Langston AA, Malone KE, Thompson JD, Daling JR, Ostrander EA. BRCA1 mutations in a population-based sample of young women with breast cancer. N Engl J Med. 1996;334:137-142. [pmid: 8531967].
143 Malone KE, Daling JR, Neal C, et al. Frequency of BRCA1/BRCA2 mutations in a population-based sample of young breast carcinoma cases. Cancer. 2000;88(6):1393-1402. [pmid: 10717622].
144 Anton-Culver H, Cohen PF, Gildea ME, Ziogas A. Characteristics of BRCA1 mutations in a population-based case series of breast and ovarian cancer. Eur J Cancer. 2000;36(10):1200-1208. [pmid: 10882857].
145 Newman B, Mu H, Butler LM, Millikan RC, Moorman PG, King MC. Frequency of breast cancer attributable to BRCA1 in a population-based series of American women. JAMA. 1998;279(12):915-921. [pmid: 9544765].
146 Sutcliffe S, Pharoah PD, Easton DF, Ponder BA. Ovarian and breast cancer risks to women in families with two or more cases of ovarian cancer. Int J Cancer. 2000;87(1):110-117. [pmid: 10861460].
147 Stratton JF, Gayther SA, Russell P, et al. Contribution of BRCA1 mutations to ovarian cancer. N Engl J Med. 1997;336(16):1125-1130. [pmid: 9099656].
148 Janezic SA, Ziogas A, Krumroy LM, et al. Germline BRCA1 alterations in a population-based series of ovarian cancer cases. Hum Mol Genet. 1999;8(5):889-897. [pmid: 10196379].
149 Gayther SA, Russell P, Harrington P, Antoniou AC, Easton DF, Ponder BA. The contribution of germline BRCA1 and BRCA2 mutations to familial ovarian cancer: no evidence for other ovarian cancer-susceptibility genes. Am J Hum Genet. 1999;65(4):1021-1029. [pmid: 10486320]. [pmcid: 1288234].
150 FitzGerald MG, MacDonald DJ, Krainer M, et al. Germ-line BRCA1 mutations in Jewish and non-Jewish women with early-onset breast cancer. N Engl J Med. 1996;334(3):143-149. [pmid: 8531968].
151 Gershoni-Baruch R, Dagan E, Fried G, et al. Significantly lower rates of BRCA1/BRCA2 founder mutations in Ashkenazi women with sporadic compared with familial early onset breast cancer. Eur J Cancer. 2000;36(8):983-986. [pmid: 10885601].
152 Abeliovich D, Kaduri L, Lerer I, et al. The founder mutations 185delAG and 5382insC in BRCA1 and 6174delT in BRCA2 appear in 60% of ovarian cancer and 30% of early-onset breast cancer patients among Ashkenazi women. Am J Hum Genet. 1997;60(3):505-514. [pmid: 9042909]. [pmcid: 1712523].
153 Robson M, Gilewski T, Hass B, et al. BRCA-associated breast cancer in young women. J Clin Oncol. 1998;16:1642-1649. [pmid: 9586873].
154 Boyd J, Sonoda Y, Federici MG, et al. Clinicopathologic features of BRCA-linked and sporadic ovarian cancer. JAMA. 2000;283(17):2260-2265. [pmid: 10807385].
155 Bish A, Sutton S, Jacobs C, Levene S, Ramirez A, Hodgson S. No news is (not necessarily) good news: impact of preliminary results for BRCA1 mutation searches. Genet Med. 2002;4(5):353-358. [pmid: 12394348].
156 Brain K, Norman P, Gray J, Rogers C, Mansel R, Harper P. A randomized trial of specialist genetic assessment: psychological impact on women at different levels of familial breast cancer risk. Br J Cancer. 2002;86(2):233-238. [pmid: 11870512].
157 Friedman LC, Webb JA, Richards CS, et al. Psychological impact of receiving negative BRCA1 mutation test results in Ashkenazim. Genet Med. 1999;1(3):74-79. [pmid: 11336456].
158 Hopwood P, Keeling F, Long A, Pool C, Evans G, Howell A. Psychological support needs for women at high genetic risk of breast cancer: some preliminary indicators. Psycho-Oncology. 1998;7(5):402-412. [pmid: 9809331].
159 Lerman C, Hughes C, Lemon SJ, et al. What you don't know can hurt you: adverse psychologic effects in members of BRCA1-linked and BRCA2-linked families who decline genetic testing. J Clin Oncol. 1998;16(5):1650-1654. [pmid: 9586874].
160 Lobb EA, Butow PN, Barratt A, et al. Communication and information-giving in high-risk breast cancer consultations: influence on patient outcomes. Br J Cancer. 2004;90(2):321-327. [pmid: 14735171].
161 Meiser B, Butow P, Friedlander M, et al. Psychological impact of genetic testing in women from high-risk breast cancer families. Eur J Cancer. 2002;38(15):2025-2031. [pmid: 12376208].
162 Smith KE, West JA, Croyle RT, Botkin JR. Familial context of genetic testing for cancer susceptibility: moderating effect of siblings' test results on psychological distress one to two weeks after BRCA1 mutation testing. Cancer Epidemiol Biomarkers Prev. 1999;8(4):385-392. [pmid: 10207644].
163 Watson M, Lloyd S, Davidson J, et al. The impact of genetic counselling on risk perception and mental health in women with a family history of breast cancer. Br J Cancer. 1999;79(56):868-874. [pmid: 10070883].
164 Bish A, Sutton S, Jacobs C, Levene S, Ramirez A, Hodgson S. Changes in psychological distress after cancer genetic counselling: a comparison of affected and unaffected women. Br J Cancer. 2002;86(1):43-50. [pmid: 11857010].
165 Fry A, Cull A, Appleton S, et al. A randomised controlled trial of breast cancer genetics services in South East Scotland: psychological impact. Br J Cancer. 2003;89(4):653-659. [pmid: 12915873].
166 Gilbert FJ, Cordiner CM, Affleck IR, Hood DB, Mathieson D, Walker LG. Breast screening: the psychological sequelae of false-positive recall in women with and without a family history of breast cancer. Eur J Cancer. 1998;34(13):2010-2014. [pmid: 10070302].
167 Lodder LN, Frets PG, Trijsburg RW, et al. One year follow-up of women opting for presymptomatic testing for BRCA1 and BRCA2: emotional impact of the test outcome and decisions on risk management (surveillance or prophylactic surgery). Breast Cancer Res Treat. 2002;73(2):97-112. [pmid: 12088120].
168 Lodder L, Frets PG, Trijsburg RW, et al. Psychological impact of receiving a BRCA1/BRCA2 test result. Am J Med Genet. 2001;98(1):15-24. [pmid: 11426450].
169 Meiser B, Butow PN, Barratt AL, et al. Long-term outcomes of genetic counseling in women at increased risk of developing hereditary breast cancer. Patient Educ Couns. 2001;44(3):215-225. [pmid: 11553422].
170 Ritvo P, Robinson G, Irvine J, et al. Psychological adjustment to familial genetic risk assessment: differences in two longitudinal samples. Patient Educ Couns. 2000;40(2):163-172. [pmid: 10771370].
171 Warner E, Carroll JC, Heisey RE, et al. Educating women about breast cancer. An intervention for women with a family history of breast cancer. Can Fam Physician. 2003;49:56-63. [pmid: 12602843]. [pmcid: 2214123].
172 Burke W, Petersen G, Lynch P, et al. Recommendations for follow-up care of individuals with an inherited predisposition to cancer. I. Hereditary nonpolyposis colon cancer. Cancer Genetics Studies Consortium. JAMA. 1997;277(11):915-919. [pmid: 9062331].
173 Brekelmans CT, Seynaeve C, Bartels CC, et al. Effectiveness of breast cancer surveillance in BRCA1/2 gene mutation carriers and women with high familial risk. J Clin Oncol. 2001;19(4):924-930. [pmid: 11181654].
174 Chart PL, Franssen E. Management of women at increased risk for breast cancer: Preliminary results from a new program. Can Med Assoc J. 1997;157:1235-1242. [pmid: 9361645]. [pmcid: 1228353].
175 Gui GP, Hogben RK, Walsh G, A'Hern R, Eeles R. The incidence of breast cancer from screening women according to predicted family history risk: does annual clinical examination add to mammography?. Eur J Cancer. 2001;37(13):1668-1673. [pmid: 11527694].
176 Kollias J, Sibbering DM, Blamey RW, et al. Screening women aged less than 50 years with a family history of breast cancer. Eur J Cancer. 1998;34(6):878-883. [pmid: 9797701].
177 Lai M, Yen M, Kuo H, et al. Efficacy of breast-cancer screening for female relatives of breast-cancer-index cases: Taiwan multicentre cancer screening (TAMCAS). Int J Cancer. 1998;78:21-26. [pmid: 9724089].
178 Lalloo F, Boggis CR, Evans DG, Shenton A, Threlfall AG, Howell A. Screening by mammography, women with a family history of breast cancer. Eur J Cancer. 1998;34(6):937-940. [pmid: 9797712].
179 Moller P, Maehle L, Heimdal K, et al. Inherited breast carcinoma—prospective findings in 1,194 women at risk. Acta Oncol. 1996;35(Suppl 8):7-11. [pmid: 9073043].
180 Saetersdal A, Dorum A, Heimdal K, et al. Inherited predisposition to breast carcinoma. Results of first round examination of 537 women at risk. Anticancer Research. 1996;16(4A):1989-1992. [pmid: 8712731].
181 Tilanus-Linthorst M, Bartels C, Obdeijn IM, et al. Earlier detection of breast cancer by surveillance of women at familial risk. Eur J Cancer. 2000;36:514-519. [pmid: 10717529].
182 Komenaka IK, Ditkoff BA, Joseph K, et al. The development of interval breast malignancies in patients with BRCA mutations. Cancer. 2004;100(10):2079-2083. [pmid: 15139048].
183 Scheuer L, Kauff N, Robson M, et al. Outcome of preventive surgery and screening for breast and ovarian cancer in BRCA mutation carriers. J Clin Oncol. 2002;20(5):1260-1268. [pmid: 11870168].
184 Pathology of familial breast cancer: differences between breast cancers in carriers of BRCA1 or BRCA2 mutations and sporadic cases. Breast Cancer Linkage Consortium. Lancet. 1997;349(9064):1505–1510.
185 Fracheboud J, de Koning HJ, Beemsterboer PM, et al. Nationwide breast cancer screening in the Netherlands: results of initial and subsequent screening 1990-1995. Int J Cancer. 1998;75:694-698. [pmid: 9495236].
186 Day NE, Williams DR, Khaw KT. Breast cancer screening programmes: The development of a monitoring and evaluation system. Br J Cancer. 1989;59:954-958. [pmid: 2736233].
187 Bourne TH, Campell S, Reynolds KM, et al. Screening for early familial ovarian cancer with transvaginal ultra sonography and colour blood flow imaging. BMJ. 1993;306(3884):1025-1029. [pmid: 8490496]. [pmcid: 1677026].
188 Wickerham DL. Tamoxifen versus raloxifene in the prevention of breast cancer. Eur J Cancer. 2002;38(Suppl 6):S20-S21. [pmid: 12409060].
189 King MC, Wieand S, Hale K, et al. Tamoxifen and breast cancer incidence among women with inherited mutations in BRCA1 and BRCA2: National Surgical Adjuvant Breast and Bowel Project (NSABP-P1) Breast Cancer Prevention Trial. JAMA. 2001;286(18):2251-2256. [pmid: 11710890].
190 Cauley JA, Lucas FL, Kuller LH, Vogt MT, Browner WS, Cummings SR. Bone mineral density and risk of breast cancer in older women: the study of osteoporotic fractures. Study of Osteoporotic Fractures Research Group. JAMA. 1996;276:1404-1408. [pmid: 8892715].
191 Cauley JA, Lucas FL, Kuller LH, Stone K, Browner W, Cummings SR. Elevated serum estradiol and testosterone concentrations are associated with a high risk for breast cancer. Study of Osteoporotic Fractures Research Group. Ann Intern Med. 1999;130:270-277. [pmid: 10068384].
192 Cauley JA, Norton L, Lippman ME, et al. Continued breast cancer risk reduction in postmenopausal women treated with raloxifene: 4-year results from the MORE trial. Multiple outcomes of raloxifene evaluation. Breast Cancer Res Treat. 2001;65(2):125-134. [pmid: 11261828].
193 Gwinn ML, Lee NC, Rhodes PH, Layde PM, Rubin GL. Pregnancy, breast feeding, and oral contraceptives and the risk of epithelial ovarian cancer. J Clin Epidemiol. 1990;43:559-568. [pmid: 2348208].
194 Whittemore AS, Harris R, Itnyre J. Characteristics relating to ovarian cancer risk: collaborative analysis of 12 US case control studies, II: invasive epithelial ovarian cancers in white women. Collaborative Ovarian Cancer Group. Am J Epidemiol. 1992;136:1184-1203. [pmid: 1476141].
195 Franceschi S, Parazzini F, Negri E. Pooled analysis of 3 European case control studies of epithelial ovarian cancer, III: oral contraceptive use. Int J Cancer. 1991;49:61-65. [pmid: 1874572].
196 Narod SA, Risch H, Moslehi R, et al. Oral contraceptives and the risk of hereditary ovarian cancer. Hereditary Ovarian Cancer Clinical Study Group. N Engl J Med. 1998;339(7):424-428. [pmid: 9700175].
197 Grabrick DM, Hartmann LC, Cerhan JR, et al. Risk of breast cancer with oral contraceptive use in women with a family history of breast cancer. JAMA. 2000;284(14):1791-1798. [pmid: 11025831].
198 Ursin G, Henderson BE, Haile RW, et al. Does oral contraceptive use increase the risk of breast cancer in women with BRCA1/BRCA2 mutations more than in other women?. Cancer Research. 1997;57(17):3678-3681. [pmid: 9288771].
199 McGuire V, Felberg A, Mills M, et al. Relation of contraceptive and reproductive history to ovarian cancer risk in carriers and noncarriers of BRCA1 gene mutations. Am J Epidemiol. 2004;160(7):613-618. [pmid: 15383404].
200 Klaren HM, van't Veer LJ, van Leeuwen FE, Rookus MA. Potential for bias in studies on efficacy of prophylactic surgery for BRCA1 and BRCA2 mutation. J Natl Cancer Inst. 2003;95(13):941-947. [pmid: 12837830].
201 Hartmann LC, Schaid DJ, Woods JE, et al. Efficacy of bilateral prophylactic mastectomy in women with a family history of breast cancer. N Engl J Med. 1999;340(2):77-84. [pmid: 9887158].
202 Hartmann LC, Sellers TA, Schaid DJ, et al. Efficacy of bilateral prophylactic mastectomy in BRCA1 and BRCA2 gene mutation carriers. J Natl Cancer Inst. 2001;93(21):1633-1637. [pmid: 11698567].
203 Struewing JP, Watson P, Easton DF, Ponder BA, Lynch HT, Tucker MA. Prophylactic oophorectomy in inherited breast/ovarian cancer families. J Natl Cancer Inst Monogr. 1995(17):33–35.
204 Brinton LA, Schairer C, Hoover R, Fraumeni JF Jr. Menstrual factors and risk of breast cancer. Cancer Invest. 1988;6:245-254. [pmid: 3167610].
205 Meijer WJ, van Lindert AC. Prophylactic oophorectomy. Eur J Obstet Gynecol Reprod Biol. 1992;47(1):59-65. [pmid: 1426512].
206 Parazzini F, Braga C, La Vecchia C, Negri E, Acerboni S, Franceschi S. Hysterectomy, oophorectomy in premenopause, and risk of breast cancer. Obstet Gynecol. 1997;90(3):453-456. [pmid: 9277661].
207 Schairer C, Persson I, Falkeborn M, Naessen T, Troisi R, Brinton LA. Breast cancer risk associated with gynecologic surgery and indications for such surgery. Int J Cancer. 1997;70(2):150-154. [pmid: 9009152].
208 Hankinson SE, Hunter DJ, Colditz G. Tubal ligation, hysterectomy and the risk of ovarian cancer. JAMA. 1993;270:2813-2818. [pmid: 8133619].
209 Rosenblatt KA, Thomas DB. Reduced risk of ovarian cancer in women with a tubal ligation or hysterectomy. The World Health Organization Collaborative Study of Neoplasia and Steroid Contraceptives. Cancer Epidemiol Biomarkers Prev. 1996;5(933–935).
210 Narod SA, Sun P, Ghadirian P, et al. Tubal ligation and risk of ovarian cancer in carriers of BRCA1 or BRCA2 mutations: a case-control study. Lancet. 2001;357(9267):1467-1470. [pmid: 11377596].
211 Law J. Cancers detected and induced in mammographic screening: new screening schedules and younger women with family history. Br J Radiol. 1997;70:62-69. [pmid: 9059297].
212 Day R. Quality of life and tamoxifen in a breast cancer prevention trial. Ann N Y Acad Sci. 2001;949:143-150. [pmid: 11795346].
213 Contant CM, Menke-Pluijmers MB, Seynaeve C, et al. Clinical experience of prophylactic mastectomy followed by immediate breast reconstruction in women at hereditary risk of breast cancer (HB(O)C) or a proven BRCA1 and BRCA2 germ-line mutation. Eur J Surg Oncol. 2002;28(6):627-632. [pmid: 12359199].
214 Eisen A, Rebbeck TR, Wood WC, Weber BL. Prophylactic surgery in women with a hereditary predisposition to breast and ovarian cancer. J Clin Oncol. 2000;18(9):1980-1995. [pmid: 10784640].
215 Weber BL. Familial breast cancer. Recent Results in Cancer Research. 1996;140:5-16. [pmid: 8787076].
216 Nelson HD. Commonly used types of postmenopausal estrogen for treatment of hot flashes: scientific review. JAMA. 2004;291(13):1610-1620. [pmid: 15069049].
217 Cauley J, Robbins J, Chen Z, et al. Effects of estrogen plus progestin on risk of fracture and bone mineral density. The Women's Health Initiative Randomized Controlled Trial. JAMA. 2003;290:1729-1738. [pmid: 14519707].
218 Chlebowski R, Hendrix SL, Langer R, et al. Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women. The Women's Health Initiative Randomized Trial. JAMA. 2003;289:3243-3253. [pmid: 12824205].
219 Committee WsHIS. Effects of conjugated equine estrogen in postmenopausal women with hysterectomy. The Women's Health Initiative Randomized Controlled Trial. JAMA. 2004;291:1701-1712. [pmid: 15082697].
220 Sellers TA, Mink PJ, Cerhan JR, et al. The role of hormone replacement therapy in the risk for breast cancer and total mortality in women with a family history of breast cancer. Ann Intern Med. 1997;127(11):973-980. [pmid: 9412302].
221 Armstrong K, Schwartz JS, Randall T, Rubin SC, Weber B. Hormone replacement therapy and life expectancy after prophylactic oophorectomy in women with BRCA1/2 mutations: a decision analysis. J Clin Oncol. 2004;22(6):1045-1054. [pmid: 14981106].
222 Stefanek ME. Bilateral prophylactic mastectomy: issues and concerns. J Natl Cancer Inst Monogr. 1995(17):37–42.
223 Eisinger F, Reynier CJ, Chabal F, Luquet C, Moatti JP, Sobol H. Acceptable strategies for dealing with hereditary breast/ovarian cancer risk. J Natl Cancer Inst. 1997;89(10):731. [pmid: 9168189].
224 Grana G, Daly M, Sands C. The role of prophylactic mastectomy in managing genetic risk. Breast Cancer Res Treat. 1994;32(Suppl):72.
225 Lerman C, Narod S, Schulman K, et al. BRCA1 testing in families with hereditary breast-ovarian cancer. A prospective study of patient decision making and outcomes. JAMA. 1996;275(24):1885-1892. [pmid: 8648868].
226 Frost MH, Schaid DJ, Sellers TA, et al. Long-term satisfaction and psychological and social function following bilateral prophylactic mastectomy. JAMA. 2000;284(3):319-324. [pmid: 10891963].
227 Borgen PI, Hill AD, Tran KN, et al. Patient regrets after bilateral prophylactic mastectomy. Ann Surg Oncol. 1998;5(7):603-606. [pmid: 9831108].
228 Hatcher MB, Fallowfield L, A'Hern R. The psychosocial impact of bilateral prophylactic mastectomy: prospective study using questionnaires and semistructured interviews. BMJ. 2001;322(7278):76. [pmid: 11154619]. [pmcid: 26594].
229 Tiller K, Meiser B, Butow P, et al. Psychological impact of prophylactic oophorectomy in women at increased risk of developing ovarian cancer: a prospective study. Gynecol Oncol. 2002;86(2):212-219. [pmid: 12144830].
230 Nathorst-Boos J, von Schoultz B, Carlstrom K. Elective ovarian removal and estrogen replacement therapy—effects on sexual life, psychological well-being and androgen status. J Psychosom Obstet Gynaecol. 1993;14(4):283-293. [pmid: 8142982].
231 Dennerstein L, Wood C, Burrows GD. Sexual response following hysterectomy and oophorectomy. Obstet Gynecol. 1977;49(1):92-96. [pmid: 831167].
232 Everson SA, Matthews KA, Guzick DS, Wing RR, Kuller LH. Effects of surgical menopause on psychological characteristics and lipid levels: the Healthy Women Study. Health Psychology. 1995;14(5):435-443. [pmid: 7498115].
233 Fry A, Busby-Earle C, Rush R, Cull A. Prophylactic oophorectomy versus screening: psychosocial outcomes in women at increased risk of ovarian cancer. Psycho-Oncology. 2001;10(3):231-241. [pmid: 11351375].
234 Statement of the American Society of Clinical Oncology, Genetic testing for cancer susceptibility. Indications for genetic testing. SEER Data, , 1994. Available at: http://seer.cancer.gov/. Accessed March 30, 2005. Table 3
235 Griffith GL, Edwards RT, Gray J. Cancer genetics services: a systematic review of the economic evidence and issues. Br J Cancer. 2004;90(9):1697-1703. [pmid: 15150621].
236 Breast and Ovarian Cancer Family Registries. Available at: http://epi.grants.center.gov/BCFR/. Accessed March 20, 2005.
237 Progeny Software, LLC. Available at: www.progeny2000.com. Accessed June 2004.
238 Eccles DM, Evans DG, Mackay J. Guidelines for a genetic risk based approach to advising women with a family history of breast cancer. UK Cancer Family Study Group (UKCFSG). J Med Genet. 2000;37(3):203-209. [pmid: 10699057]. [pmcid: 1734545].
239 Moller P, Evans G, Haites N, et al. Guidelines for follow-up of women at high risk for inherited breast cancer: consensus statement from the Biomed 2 Demonstration Programme on Inherited Breast Cancer. Disease Markers. 1999;15(13):207-211. [pmid: 10595280].
240 Fries MH, Holt C, Carpenter I, et al. Guidelines for evaluation of patients at risk for inherited breast and ovarian cancer: recommendations of the Department of Defense Familial Breast/Ovarian Cancer Research Project. Military Medicine. 2002;167(2):93-98.
241 Lucassen A, Watson E, Harcourt J, Rose P, O'Grady J. Guidelines for referral to a regional genetics service: general practitioners respond by referring more appropriate cases. Family Practice. 2001;18(2):135-140. [pmid: 11264262].
242 Elwyn G, Iredale R, Gray J. Reactions of general practitioners to a triage-controlled referral system for cancer genetics. Family Practice. 2002;19(1):65-71. [pmid: 11818352].
243 Bowen D, McTiernan A, Burke W, et al. Participation in breast cancer risk counseling among women with a family history. Cancer Epidemiol Biomarkers Prev. 1999;8(7):581-585. [pmid: 10428194].
244 Daling JR, Malone KE, Voigt LF, White E, Weiss NS. Risk of breast cancer among young women: relationship to induced abortion. J Natl Cancer Inst. 1994;86:1584-92. [pmid: 7932822].
245 Brinton LA, Daling JR, Liff JM, et al. Oral contraceptives and breast cancer risk among younger women. J Natl Cancer Inst. 1995;87:827-35. [pmid: 7791232].
246 Wacholder S, Hartge P, Struewing JP, et al. The kin-cohort study for estimating penetrance. Am J Epidemiol. 1998;148(7):623-630. [pmid: 9778168].
247 Offit K. Breast cancer and BRCA1 mutations. N Engl J Med. 1996;334(18):1197-1198. [pmid: 8602196].
248 Ries LAG, Eisner MP, Kosary CL, Hankey BF, Miller BA, Clegg L, et al. SEER cancer statistics review, 1975-2001. Bethesda, MD: National Cancer Institute; 2004. Available at: http://seer.cancer.gov/csr/1975_2001. Accessed October 19, 2004.