# Acknowledgments

This Evidence Synthesis was funded by the U.S. Centers for Disease Control and Prevention (CDC) in partnership with the Agency for Healthcare Research and Quality (AHRQ) for the U.S. Preventive Services Task Force (USPSTF), and the investigators acknowledge the contributions of Ralph Coates, PhD, Liaison, CDC, and Gurvaneet Randhawa MD, MPH, Task Order Officer, AHRQ. Members of the USPSTF who served as leads for this project include Russell Harris, MD, MPH; Paul Frame, MD; Judith Ockene, PhD; Ned Calonge, MD, MPH; and Mark Johnson MD, MPH. The investigators thank Wylie Burke, MD, PhD, and Mark Helfand, MD, MS, for serving as consultants; expert reviewers listed in Appendix of this report for commenting on draft versions; Andrew Hamilton, MLS, MS, for conducting the literature searches; and Peggy Nygren, MA, and Kim Villemyer for assisting with the manuscript.

## Request for Reprints

Reprints are available from the AHRQ Web site at www.ahrq.gov (click on Preventive Services) and in print through the AHRQ Publications Clearinghouse (call1-800-358-9295).