# Discussion

## Conclusions

Little is known about BRCA mutations in the general population, and most data originate from studies of highly selected women with existing cancer or strong family histories of cancer. A primary care approach to screening has not yet been tested. Several tools determining individual risks for possessing mutations have been developed from databases of women with BRCA mutations. Mutation testing for those with 10% or more probability by these estimations is considered an appropriate threshold by experts in the field.^234^ Risk assessment tools are recommended as an adjuvant to genetic counseling^100^ and have not been widely evaluated for use in risk stratification in primary care settings. Women assessed as high risk in primary care settings may not necessarily be candidates for mutation testing, but could be offered more definitive risk assessment by referral to genetic counseling or application of detailed risk assessment instruments. Referral guidelines have been developed for use in primary care settings, however, no consensus or gold standard exists and their accuracy and effectiveness are not known. Risk assessment, genetic counseling, and mutation testing did not cause adverse psychological outcomes, and counseling improved distress and risk perception in the highly selected populations studied.

Although studies of BRCA mutation prevalence are limited, several studies of penetrance have been published for the general population as well as specific populations, such as Ashkenazi Jewish women. To determine estimates of cancer occurrence for women with average, moderate, and high family history risks for mutations to calculate benefits and adverse effects of screening, penetrance was estimated in a meta-analysis. This approach provided an alternative way to estimate penetrance from heterogeneous studies that used a variety of methods to estimate penetrance and utilized differing populations and techniques of BRCA mutation testing. The analysis considered BRCA1 and BRCA2 mutations separately and combined, Ashkenazi Jewish and general populations separately, ovarian and breast cancer outcomes, and penetrance to age 40 (breast cancer) or 50 (ovarian cancer) and age 75 (both breast and ovarian cancer).

Currently available prevention interventions for women identified with clinically significant BRCA mutations include intensive screening, chemoprevention with SERMs, and prophylactic mastectomy and oophorectomy. Randomized controlled trials of SERMs used different eligibility criteria utilizing family history information to varying degrees. None of the chemoprevention trials evaluated BRCA mutation status prospectively. A meta-analysis of chemoprevention trial results indicated a statistically significant effect of SERMs in preventing breast cancer and estrogen receptor-positive breast cancer. Results also indicated significantly increased risks for thromboembolic events and, for tamoxifen, endometrial cancer. Observational studies of prophylactic surgeries indicated reduced risk of breast and ovarian cancer in mutation carriers.

Since no trials of screening for BRCA mutations in the general population are available to provide direct measures of benefits and adverse effects, data obtained from the evidence synthesis were utilized in an outcomes table. Estimating prevalence and penetrance and stratifying by average, moderate, and high family risk groups are attempts to determine the yield of screening in populations that would present to primary care clinicians. Applying these estimates to outcomes tables that consider treatment effects and adverse events provides calculations of benefits and adverse effects for main outcomes. The NNS to prevent one case of breast or ovarian cancer is high among low-risk women and decreases as risk increases, as expected. Adverse effects also increase as more women are subjected to therapies. Although the outcomes table estimations can be helpful in determining benefits and adverse effects, caution is necessary in extrapolating too far from the primary data. Data are limited in describing the range of risk associated with BRCA mutations, genetic heterogeneity, and moderating factors outside the gene, among many other limitations described below.

## Limitations of the Literature and Analysis

The quality and generalizability of studies evaluated in the evidence synthesis vary substantially and may not support the assumptions made for the outcomes table. Although several risk assessment tools are available, most were designed for specialists and studies of their use and effectiveness in stratifying patients in primary care settings are lacking. Each method of risk stratification is subject to misclassification, and few data are available to guide clinicians in the best approach. Studies of the effectiveness of genetic counseling, as a second step in screening, on patient decisions and outcomes are also lacking.

Most studies of BRCA mutation testing were conducted on highly selected samples of women, many with preexisting breast or ovarian cancer or from previously identified kindreds when they were tested. The meta-analysis attempted to determine the effect of testing women selected for family history on penetrance estimates by separating studies that included women with a known cancer family history from unselected populations. Results were similar, although data were limited to make such comparisons (Table 6). Risk was often based on self-reported information, thus the accuracy of risk stratification is limited by the accuracy of reported family history in each study. In some cases, data to determine penetrance came exclusively from one study, and when multiple studies were available, they were heterogeneous. Estimates may therefore, be unreliable. Most studies used research laboratory techniques to detect clinically significant mutations that differ from the DNA sequencing available clinically, potentially underestimating prevalence by one-third.^27^ Clinical significance of mutations was determined by each study, and was based on likely functional significance and/or previous evidence of increased cancer risk, although definitions were fairly consistent across studies (Appendix I). Most importantly, it is not known how the results of studies based on these highly selected women in research settings translate to a general screening population.

Data are also not available to determine the optimal age to test and how the age at testing influences estimates of benefits and adverse effects. All estimates in the outcomes table are based on cases of cancer, not mortality. It is not known whether screening for BRCA mutations reduces cause-specific or all cause mortality and improves quality of life. The harms associated with receiving a false negative test result (12–15% with DNA sequencing), or a result indicating mutations of unknown significance (approximately 13%), are not known.

The outcomes table does not include non-quantitative measures of benefit or harm including ELSI. Although a wide-range of ELSI topics has been identified, data are limited. Despite concern about insurance and employment discrimination as a result of assessment or testing for BRCA mutations, little information is available to evaluate this risk. Existing data on benefits and adverse effects are drawn primarily from highly selected groups of well-educated Caucasian women who volunteer for studies. Very little data are available from women in the general population or minority women.

Existing evidence shows that most women do not experience adverse effects from BRCA risk assessment, counseling, and testing. In contrast, most seem to benefit from this process and report decreased breast cancer worry, decreased anxiety, and more accurate perceptions of breast cancer risk. However, the long-term impact is unknown because most studies followed patients for less than 1 year. In addition, current studies do not evaluate psychological aspects of medical outcomes, and little data are available on the impact of testing on family members.

Treatment effects are influenced by several variables that are not available and not easily factored into an outcomes table. The effectiveness of risk-reducing oophorectomy is dependent on the age at which the procedure is performed, and it becomes less effective when performed after menopause.^72^ The type of treatment selected may vary with the mutation. Women with BRCA1 mutations have a higher risk of ovarian cancer than those with BRCA2 mutations^130^ and may be more likely to elect oophorectomies. Chemoprevention is most effective in preventing estrogen receptor-positive breast tumors, although it has not been specifically evaluated in women with BRCA mutations. The proportion of estrogen receptor-positive tumors varies from 28% of those among women with BRCA1 mutations to 63% with BRCA2 mutations.^189^ It is not known how these differences influence patient decisionmaking. Although estimates of patient compliance with different interventions in the outcomes table were based on findings in the research literature, these may be significantly different in practice.

There is limited information about the cost-effectiveness of screening programs. A systematic review of economic research of cancer genetics services identified 12 studies that included economic evaluation of some aspect of BRCA1 or BRCA2 mutation testing and/or follow-up interventions, and 3 studies related to familial breast cancer.^235^ Studies focused on genetic testing and genetic counseling, and modeling health outcomes of intensive screening and prevention. Cost-effectiveness was mainly influenced by targeting genetic services for patients with a strong family history of cancer, and was affected by a number of other factors such as outcome measures used, estimated outcomes, mutation penetrance, mutation prevalence, accuracy and cost of testing, number of patients counseled per healthy mutation carrier, frequency of clinical surveillance, interventions used as well as their uptake and effectiveness, and the age at which the individual has testing and prophylactic surgery.

## Future Research

In order to determine the appropriateness of risk assessment and screening for BRCA mutations in primary care, more information is needed about mutation prevalence and impact in the general population. Research has focused on highly selected women in referral centers and generally reported short-term outcomes. Issues such as access to testing, effectiveness of screening approaches including risk stratification, use of system supports, and patient acceptance and education require additional study. Who should perform risk assessment and genetic counseling services, how should it be done, and what skills are needed are unresolved questions. Trials comparing types of providers and protocols could address these issues. What happens after patients are identified as high risk in clinical settings is also not known. The consequences of genetic testing on individuals and their relatives require more study. Well-designed investigations using standardized measures and enrolling subjects that reflect the general population, including minority women, are needed.

An expanded database or registry of patients receiving genetic counseling for inherited breast and ovarian cancer susceptibility or tested for BRCA mutations would provide useful information about predictors of cancer, response to interventions, and other modifying factors for cancer. Although all patients clinically tested in the U.S. through direct DNA sequencing utilize a single laboratory, a centralized database with key variables to address these issues is not maintained. Current research resources that may help address some of these questions include the National Cancer Institute-funded Cancer Genetics Network^87^ and Breast and Ovarian Cancer Family Registries.^236^ Additional data from women of varying socioeconomic, racial, and ethnic groups is needed. Currently available risk prediction tools and interventions may not apply to these populations.

Additional research on interventions is needed including chemoprevention trials of mutation carriers, evaluation of the effect of age at intervention on outcomes, and measurement of long-term outcomes. Studies of factors related to acceptance of preventive interventions based on genetic information would be useful, such as determining if cancer incidence in relatives is reduced because they adopt preventive interventions. This information could improve patient decisionmaking and lead to better health outcomes.