# Results

## Key Question 1. Does risk assessment and BRCA mutation testing lead to a reduction in the incidence of breast and ovarian cancer and cause-specific and/or all cause mortality?

Although several studies describe risk assessment methods that are relevant to primary care, none demonstrate that a screening approach enlisting risk assessment in a primary care setting followed by BRCA mutation testing and preventive interventions for appropriate candidates ultimately leads to a reduction in the incidence of breast and ovarian cancer and cause-specific and/or all cause mortality.

## Key Question 2. What are the ethical, legal, and social implications of genetic screening for breast and ovarian cancer susceptibility?

A total of 229 studies of ethical, legal, and social implications (ELSI) of genetic screening were identified by the literature searches, reference lists, and experts. Studies pertinent to specific key questions are described in appropriate sections of this report (Key Questions 3b, 4, and 6).

## Key Question 3a. How well does risk assessment for cancer susceptibility by a clinician in a primary care setting select candidates for BRCA mutation testing?

### Determination of Family History

Family history of breast and ovarian cancer is the most important factor for determining risk for a deleterious BRCA mutation in a woman without cancer or known family mutation. For women with first-degree relatives with cancer, the relative risks for cancer have been estimated in meta-analyses as 2.1 (2.0–2.2) for breast cancer^8^ and 3.1 (2.6–3.7) for ovarian cancer.^90^ Decisions about referral, testing, and prevention interventions are often based on self-reports of family histories that include types of cancers, relationships within the family, and ages of onset. Appropriate decisions rely on family histories that are accurately reported by women and correctly obtained by clinicians.

The accuracy of family cancer history information was addressed in a systematic review of studies of validated self-reported family histories.^91^ One study determined the sensitivity and specificity of a family history of breast or ovarian cancer in first-degree relatives reported by healthy individuals.^92^ A report of breast cancer in a first-degree relative had a sensitivity of 82%, specificity of 91%, positive likelihood ratio of 8.9 (5.4–15.0), and a negative likelihood ratio of 0.20 (0.08–0.49).^92^ A report of ovarian cancer in a first-degree relative was less reliable, and had a sensitivity of 50%, specificity of 99%, positive likelihood ratio of 34.0 (5.7–202.0), and a negative likelihood ratio of 0.51 (0.13–2.10).^92^ Overall, accuracy was better in studies concerning first-degree rather than second-degree relatives.^91^

### Tools to Assess Risk of BRCA Mutation

Although several tools to predict risk for deleterious BRCA mutations have been developed from data on previously tested women, no studies of their effectiveness in a screening population in a primary care setting are available.^93^ Much of the data used to develop the models are from women with existing cancer. Models with potential clinical applications are described in Table 2.

Table 2 Tools to Assess Risk of BRCA Mutation

Tool | Reference | Administration | Applications | Description
Myriad Genetic Laboratories (BRCA1) | Shattuck-Eidens et al, 1997^35^ | Questions | Proband must be affected with breast cancer and/or ovarian cancer. Applicable to families with small numbers of affected members. | Logistic regression model developed from data from women with early-onset breast and/or ovarian cancer and with a family history of breast and/or ovarian cancer.
Myriad Genetic Laboratories (BRCA1 and BRCA2) | Frank et al, 1998^94^ Srivastava et al, 2001^34^ | Questions | Proband must be affected with breast cancer < 50 years of age and/or ovarian cancer. Applicable to families with 2 first degree relatives with breast cancer < 50 years of age or ovarian cancer. | Logistic regression model developed from data from women with early onset breast cancer and/or ovarian cancer with ≥+E9 2 first or second degree relatives with early breast or ovarian
Couch Model (BRCA1and BRCA2) | Couch et al, 1997^36^ Blackwood et al, 2001^95^ | Questions | Proband with or without breast or ovarian cancer. Applicable to families with ≥ 1 case(s) of breast cancer and Ashkenazi Jewish ancestry. | Logistic regression model based on data from women diagnosed with breast cancer and a family history of breast and/or ovarian cancer. Includes probability tables with estimates of the likelihood of finding a BRCA1 mutation in individual families. Uses age at diagnosis and considers Ashkenazi Jewish ancestry.
BRCAPRO (BRCA1 and BRCA2) | Berry et al, 1997,^96^ 2002^97^ Parmigiani et al, 1998^98^ CancerGene^101^ | Computer program | Proband may or may not have breast or ovarian cancer. Applicable to a variety of families. | Bayesian model utilizing first and second degree family history including breast cancer, ovarian cancer, age at diagnosis, ethnicity, and size of family to estimate the age-specific probability of finding a BRCA mutation. Generates conditional or posterior probabilities. Assuming that penetrance and prevalence functions used by BRCAPRO are accurate, it misses at most an estimated 15% of mutations. Excludes paternal transmission of cancer. Validated in populations with families with breast cancer.
Cyrillic 3 Software Program (BRCAPRO and MENDEL) | www.cyrillicsoftware.com 102 | Computer program | NR | Integrated risk assessment allows creation of pedigrees for individual, family, and disease data.
Progeny Software (BRCA1 and BRCA2) | www.progeny2000.com237 | Computer program | NR | Allows for creation of pedigrees for individual, family, and disease data.
Unnamed (BRCA1 and BRCA2) | Tyrer et al, 2004^103^ | Computer program | Proband may or may not have breast or ovarian cancer. Applicable to a variety of families. | Bayesian model incorporating BRCA 1 and BRCA2 genes, a low penetrance gene, and personal risk factors to produce a likelihood of carrying genes predisposing to breast cancer, and therefore also likelihood of developing breast cancer.

NR, not reported.

### Myriad Genetic Laboratories Models

Logistic regression models have been developed by the Myriad Genetic Laboratories,^34,^ ^35,^ ^94^ a commercial laboratory in the U.S. providing DNA full sequence testing for BRCA mutations. One model predicts risk for BRCA1 mutation and is based on a population of women with either early-onset breast cancer or ovarian cancer, or with a family history of breast or ovarian cancer.^35^ This model also takes into account bilateral breast cancer, age of diagnosis, and Ashkenazi Jewish ancestry, and is not dependent on affected relatives. A second Myriad model predicts risk for both BRCA1 and BRCA2 mutations and is based on a population of women with breast cancer under age 50 or ovarian cancer who have at least one first- or second-degree relative with early breast or ovarian cancer.^34,^ ^94^ This model considers bilateral breast cancer, concurrent breast and ovarian cancer, and breast cancer under age 40.

Couch Model. The Couch Model is based on logistic regression of data from a population of women with breast cancer and a family history of breast and/or ovarian cancer, and predicts risk for BRCA1 mutation.^36^ Mutations were originally determined by conformation sensitive gel electrophoresis (CSGE) rather than DNA full sequencing, potentially underestimating mutation prevalence. A refined model now includes both BRCA1 and BRCA2 mutations using DNA full sequencing.^95^ In this model, the individual may or may not have breast or ovarian cancer, but the family must have more than two cases of breast cancer. Predictors include the number of women diagnosed with breast cancer under age 50, concurrent breast and ovarian cancer, ovarian cancer, male breast cancer, and Ashkenazi Jewish ancestry.

BRCA PRO. BRCAPRO is a Bayesian model providing estimates of risk for BRCA1 and BRCA2 mutations^96^–^98^ that has been validated in populations of women with increased prevalence of specific mutations.^97,^ ^99^ The performance of BRCAPRO was compared with evaluations by cancer risk counselors in 148 pedigrees with women affected by breast or ovarian cancer who had BRCA mutation analysis. Using a greater than 10% BRCA gene mutation probability threshold, the sensitivity for identifying mutation carriers was 94% for counselors and 92% for BRCAPRO, and specificity was 16% for counselors and 32% for BRCAPRO.^99^ Studies are currently under way to evaluate BRCAPRO estimates compared with other models.^100^ In BRCAPRO, the individual may or may not have breast or ovarian cancer, and it considers current age, age at diagnosis, bilateral breast cancer, concurrent breast and ovarian cancer, all first- and second-degree relatives with and without cancer, males with breast cancer, and Ashkenazi Jewish ancestry. It includes information on both affected and unaffected relatives. CancerGene is a user-friendly software program^101^ that provides prior probabilities from BRCAPRO, but is much easier to use. A new version of Cyrillic software (Cyrillic 3) also includes BRCAPRO.^102^

Tyrer Model. This model integrates personal risk factors with a genetic analysis to provide a comprehensive risk estimate.^103^ Personal risk factors include current age, age at menarche, parity, age at first childbirth, age at menopause, atypical hyperplasia, lobular carcinoma in situ, height, and body mass index (BMI). The individual may or may not have breast or ovarian cancer. Genetic analysis incorporates the high-risk, high-penetrance BRCA1 and BRCA2 germline mutations with the addition of a low-penetrance gene. This was created as a stand-in to account for the effect of all other unidentified genes. Methods include segregation analysis techniques based on Bayes' theorem. This model is accessible through a computer program that is not yet widely distributed, but available from the investigators.

### Tools for Primary Care That Assess Risk and Guide Referral

The family history assessment tool (FHAT) was developed to assist clinicians in selecting patients for referral to genetic counseling.^104^ The referral threshold was doubling of the general population lifetime risk for breast cancer or ovarian cancer (22%) as estimated by Claus^105^ and BRCAPRO methods. With FHAT, points are assigned according to the number of relatives, third-degree relatives or closer, diagnosed with breast, ovarian, colon, or prostate cancer, and the relationship to the proband, age at diagnosis, and type and number of primary cancers. Patients with scores of 10 or more points warrant referral. Results of FHAT were compared with Claus and BRCAPRO estimates for 184 women with incident familial and non-familial breast cancer.^104^ The sensitivity and specificity of FHAT for a clinically significant BRCA1 or BRCA2 mutation were 94% and 51%, respectively. This compares with sensitivity and specificity of 74% and 79% for a 20% threshold for having a clinically significant BRCA1 or BRCA2 mutation using BRCAPRO, and 74% and 54% using Claus.

The Manchester scoring system was developed in the U.K. to predict deleterious BRCA1 or BRCA2 mutations at the 10% likelihood level.^106^ Points are assigned depending on type of cancer (breast, ovarian, pancreatic, or prostate), affected family members, and age at diagnosis and provide scores for BRCA1 and BRCA2 mutations separately. The scoring system was validated in three sample sets in other regions of the U.K. and compared with other existing models. The Manchester model (combined BRCA1 and BRCA2) had 87% sensitivity and 66% specificity, comparing well with other models tested, including BRCAPRO with 61% sensitivity and 44% specificity.

Risk Assessment in Genetics (RAGs) is a computer program designed to support assessment and management of family breast and ovarian cancer in primary care settings.^107^ It generates pedigrees after information about the proband and relatives are entered, categorizes risks of breast and ovarian cancer, generates referral guidelines based on the Claus model, and suggests appropriate management. Scores from RAGs are based on family history of affected relatives and the age of the presenting patient. One of three risk levels is assigned: low (<10% risk of having a clinically significant BRCA1 or BRCA2 mutation), in which the patient is reassured and managed in primary care; moderate (10–25% risk), in which the patient is referred to a breast clinic; and high (>25% risk), in which the patient is referred to a clinical geneticist.^108^ A study of a small random sample of general practitioners in the U.K. compared how well they managed 18 simulated cases using RAGs, Cyrillic, and pen and paper approaches.^109^ RAGs resulted in significantly more appropriate management decisions and more accurate pedigrees, and was the preferred approach.^109^ RAGs took 178 seconds (mean) to administer, which was longer than pen and paper but shorter than Cyrillic.^109^

### Referral Guidelines

Referral guidelines have been developed by health maintenance organizations (HMOs),^110^ professional organizations,^31,^ ^32^ cancer programs,^111,^ ^112^ state and national health programs,^113^–^116^ and investigators^117^ to assist primary care clinicians in identifying women at potentially increased risk for BRCA mutations (Table 3). Although specific items vary among the guidelines, most include questions about personal and family history of BRCA mutations, breast and ovarian cancer, age of diagnosis, bilateral breast cancer, and Ashkenazi Jewish heritage. Most guidelines are intended to lead to a referral for more extensive genetic evaluation and counseling, not directly to testing. There is currently no consensus or gold standard about the use of guidelines. The effectiveness of this approach has not been evaluated.

Table 3 Criteria for Referral for Breast and Ovarian Cancer Genetic Counseling and Testing*

Criteria supporting a referral for breast and ovarian cancer genetic counseling | HMO sites^†, 110^ | | | | | Other groups‡
| A | B | C | D | E | NCCN High Risk Assessment^112^ | New York State ACMG^113^ | UK Cancer Family Study Group^238^ | Leiden WPHT^115^ | Biomed 2 DPIBC^239^ | Dept of Defense FBOCRP^240^ | Oxford Regional Genetics Service^241^ | All-Wales Cancer Genetics Service^242^ | National Breast Cancer Centre^114^ | Hampel Review^117^
Women with a family history (but no personal history) of breast and/or ovarian cancer in maternal or paternal relatives as defined by at least one of the following:
Breast cancer in at least 2 first- or second-degree relatives, with at least 2 diagnosed at age 49 or younger, and at least one of the relatives is first-degree. | X | X | X | X | | X | X | | | X | | X | X | X | X
Breast cancer in 3 or more first- or second-degree relatives, with at least one diagnosed at age 49 or younger. | X | X | X | X | | X | X | X | X | X | | X | X | X | X
Breast cancer in 1 or more first-degree relatives. | | | | | X | X | X
Ovarian cancer in at least 2 first- or second-degree relatives, diagnosed at any age. | X | X | X | X | | X | X | | | | | | X | X | X
Ovarian cancer in 1 or more first-degree relatives. | | | | | X | X | X
Breast cancer in at least one first- or second-degree relative, and ovarian cancer in at least one first- or second-degree relative. | X | X | X | X | | X | X | X | | X | | X | X | X | X
Delineates persons unacceptable for referral. | X | X | X | X | | X | X | X | X | X | X | X | X | X | X
Counseling required pre and/or post genetic test. | X | X | X | | X | X | X | X | | X | X | | | X
Affected relative be tested first. | | | X | | X
Informed consent required prior to testing. | X | X | X | X | X
Provides medical management recommendations for mutation carriers. | X | | X | X | X | X | X | X | | X | X | X
Additional recommendations within the guideline. | | | | | | X | X | X | X | X | X | X | X | X | X

* Adapted from Mouchawar et al, 2003^110^

† Plans A, B, C, D: cancer genetic counseling referral guidelines for BRCA genes; E: counseling and testing guidelines for BRCA genes.

‡ National Comprehensive Cancer Network (NCCN), 2003^112^; New York State Department of Health, American College of Medical Genetics (ACMG), 1999^113^; Leiden Working Party of Hereditary Tumors (WPHT), the Netherlands. Guidelines for women without breast cancer ^115^; Biomed 2 Demonstration Programme on Inherited Breast Cancer (DPIBC), Norway^239^; Department of Defense Familial Breast/Ovarian Cancer Research Project (FBOCRP)240; National Health and Medical Research Council, National Breast Cancer Centre, 2000 Australia.^114^

## Key Question 3b. What are the benefits of genetic counseling prior to testing?

No studies describe cancer or mortality outcomes related to genetic counseling, although 10 randomized controlled trials reported psychological and behavioral outcomes (Appendix G). Of these, 4 met criteria for good quality^41,^ ^118^–^120^ and 6 for fair quality (Appendix H).^38^–^40,^ ^42^–^44^ Trials examined the impact of genetic counseling on breast cancer worry, anxiety, depression, perception of cancer risk, and intent to participate in genetic testing. Trials were conducted in highly selected samples of women, and results may not generalize to a screening population.

The trial most applicable to primary care practice randomized women at risk for clinically significant BRCA mutations to two groups and compared the effectiveness of a computer-based decision aid with standard genetic counseling.^120^ The decision aid could potentially be used in primary care settings. Although knowledge scores increased in both groups, the decision aid was more effective than standard genetic counseling for increasing knowledge of breast cancer and genetic testing among women at low risk (<10% chance of deleterious BRCA mutation) (p=0.03), but not among women at high risk (≥10% chance). Perception of risk and intention to test were significantly lower for low-risk women using either method. The numbers of women undergoing mutation testing 1 month or 6 months after the intervention did not differ by type of intervention. Standard genetic counseling was more effective than the decision aid at reducing anxiety, although anxiety scores were within normal ranges for both groups at baseline and after either intervention.

### Psychological Benefits

Results of nine trials indicated either decreased measures of psychological distress or no effect after genetic counseling (Table 4). Five of seven trials showed decreased breast cancer worry after genetic counseling,^38,^ ^42^–^44,^ ^119^ and two showed no significant effect.^40,^ ^118^ Three studies reported decreased anxiety after genetic counseling,^38,^ ^118,^ ^120^ and three reported no significant effect.^41,^ ^43,^ ^119^ One study reported decreased depression after genetic counseling,^118^ and four found no significant effect.^38,^ ^41,^ ^43,^ ^119^ These findings are consistent with a recent meta-analysis of 12 published studies on genetic counseling for breast cancer with randomized controlled trial or prospective study designs.^121^ Results indicated that genetic counseling led to significant decreases in generalized anxiety (average weighted effect; r = -0.17, p<0.01), although the reduction in psychological distress was not significant (r = -0.074, p<0.052).

Table 4 Randomized Controlled Trials of Genetic Counseling: Benefits, Adverse Effects, and Impact on Risk Perception

Author, year | N | History of cancer | Provider of genetic counseling | Measures | Breast cancer worry | | Anxiety | | Depression | | Perception of risk | | Intention to participate in genetic testing | | Quality rating
| | | | | Increase | Decrease | Increase | Decrease | Increase | Decrease | More accurate | Less accurate | Increase | Decrease
Bowen et al, 2004^38^ | 354 | Family | Genetic Counselor or Mental Health Counselor | BCWS, BSI, SRE | 0 | X | 0 | X | 0 | 0 | X | 0 | NR | NR | Fair
Bowen et al, 2002^39^ | 357 | Family | Genetic Counselor | SRE | NR | NR | NR | NR | NR | NR | NR | NR | 0 | X | Fair
Burke et al, 2000^40^ | 356 | Family | Genetic Counselor | SRE | 0 | 0 | NR | NR | NR | NR | X | 0 | NR | NR | Fair
Cull et al, 1998*^, 41^ | 144 | NR | Genetic Counselor | GHQ, SRE, STAI | NR | NR | 0 | 0 | 0 | 0 | X^†^ | X^‡^ | NR | NR | Good
Green et al, 2004^120^ | 211 | Family or Personal | Genetic Counselor or computer-based decision aid | NSI, SRE, STAI | NR | NR | 0 | X | NR | NR | X | 0 | 0 | X | Good
Lerman et al, 1999^42^ | 364 | Family | Nurse Educator | IES, NSI | 0 | X | NR | NR | NR | NR | NR | NR | X | 0 | Fair
Lerman, 1996^43^ | 124 | Family | Nurse Educator | IES, POMS, SRE | 0 | X | 0 | 0 | 0 | 0 | 0 | 0 | NR | NR | Fair
Lerman et al, 1995^44^ | 227 | Family | Nurse Educator | IES, SRE | 0 | X | NR | NR | NR | NR | X | 0 | NR | NR | Fair
Lobb et al, 2002*^, 118^ | 195 | Family, Personal, or None | Clinical Geneticist/Genetic Counselor | HADS, IES, SRE | 0 | 0 | 0 | X | 0 | X | 0 | X^#^ | NR | NR | Good
Watson et al, 1998*^,^ ^119^ | 115 | Family | Genetic Counselor | BCWS, GHQ, SRE | 0 | X | 0 | 0 | 0 | 0 | X** | 0 | NR | NR | Good

BCWS, Breast Cancer Worry Scale; BSI, Brief Symptom Inventory; GHQ, General Health Questionnaire (12-, 28-, or 30-item); HADS, Hospital Anxiety and Depression Scale; IES, Impact of Events Scale (breast cancer specific distress); NSI, non-standardized instrument; POMS, Brief Profile of Mood States; SRE, Subject Risk Estimate (instrument not standardized, administration varies by study); STAI, State-Trait Anxiety Inventory.

X, significant relationship; 0, studied but not significant; NR, not reported.

* Study done in a country other than the United States (e.g. Scotland, Australia, or England).

† Both treatment groups at treatment end.

‡ Video after counseling subjects at 1-month follow-up.

§ Subjects in low-risk group only.

║ African American subjects only.

¶ Subjects who listened to audio tape.

# Unaffected subjects only.

** Risk provided as odds ratio.

### Perception of Cancer Risk

Women often overestimate their risk of breast cancer and/or deleterious BRCA mutations.^43,^ ^89,^ ^122^ Most women responding to surveys, including those at average and moderate risk, report a strong desire for genetic testing^38,^ ^123^ even though only those at high risk would potentially benefit.

Five trials reported increased accuracy of cancer risk perception among women who received genetic counseling,^38,^ ^40,^ ^44,^ ^119,^ ^120^ implying that genetic counseling may improve the predictive value of testing by reducing testing in moderate- or average-risk individuals. One study showed less accurate risk perception after genetic counseling, ^118^ and one had mixed results.^41^ Three studies examining the intention to participate in genetic testing after counseling reported inconsistent results. One study indicated a decrease in intention,^39^ another showed an increase in intention among African American, but not Caucasian women,^42^ and the third study showed decreased intention among low-risk but not high-risk women.^120^

## Key Question 3c. Among women with family histories predicting either an average, moderate, or high risk for a deleterious mutation, how well does BRCA mutation testing predict risk of breast and ovarian cancer?

Cancer risk in family history risk groups can be estimated by determining the prevalence of the mutation and its penetrance for breast and ovarian cancer for each risk group. A total of 38 studies of prevalence and penetrance were identified as relevant to this question (Appendixes I–L). These studies could not be rated for quality because their study designs are not addressed by the USPSTF criteria. Most studies used research laboratory techniques to detect clinically significant mutations that differ from the DNA sequencing available clinically. The prevalence of clinically significant mutations may be underestimated by one-third using these techniques.^124^

### Prevalence

#### General Population

No direct measures of the prevalence of clinically significant BRCA1 or BRCA2 mutations in the general, non-Jewish U.S. population have been published. Models estimate it to be about 1 in 300 to 500.^27^–^30^ For BRCA1, one model estimates a 0.12% prevalence rate.^25^ The prevalence among those with a strong family history of cancer is estimated to be 8.7% based on one report of clinical referral populations that considered both BRCA1 and BRCA2 mutations together.^33^ Additional prevalence estimates for individuals from referral populations with various levels of family history range from 3.4% (no breast cancer diagnosed in relatives younger than age 50, no ovarian cancer) to 15.5% (breast cancer diagnosed in a relative younger than age 50 and ovarian cancer diagnosed at any age).^46^ Based on these estimates, the prevalence of BRCA1 and BRCA2 mutations in women at average risk could be considered as up to 0.24%, moderate risk from 0.24% to 3.4%, and high risk as 8.7% and above (Table 5). In the absence of direct measures, it can be assumed that one-half of the mutations would be in BRCA1 and one-half in BRCA2.

Table 5 Results of Meta-Analysis of Prevalence Studies

Risk for mutation* | BRCA1 | | BRCA2 | | BRCA1 or BRCA2
| No. studies | Prevalence (%, 95% CI) | No. studies | Prevalence (%, 95% CI) | No. studies | Prevalence (%, 95% CI)
Average Risk
| | 0.03^†^ | | 0.03^†^ | | 0.06^†^
| | 0.06^†^ | | 0.06^†^ | | 0.12^†^
| | 0.09^†^ | | 0.09^†^ | | 0.18^†^
| 1^24^ | 0.12 | 1^24^ | 0.12 | 1^24^ | 0.24
Moderate Risk
Ashkenazi Jewish | 5^11,^ ^12,^ ^125^–^127^ | 0.82 (0.53, 1.28) | 6^11,^ ^12,^ ^125^–^128^ | 1.13 (0.88, 1.44) | 4^11,^ ^12,^ ^125,^ ^127^ | 1.92 (1.31, 2.82)
General Population
Low prevalence estimate | 1^24^ | 0.12 | 1^24^ | 0.12 | 1^24^ | 0.24
| | 0.50^†^ | | 0.50^†^ | | 1.00^†^
| | 0.75^†^ | | 0.75^†^ | | 1.50^†^
| | 1.00^†^ | | 1.00^†^ | | 2.00^†^
| | 1.70^†^ | | 1.70^†^ | | 3.40^†^
High prevalence estimate | 0 | 1.28^‡^ | 0 | 2.12^‡^ | 0 | 3.40^‡^
High Risk
Ashkenazi Jewish | 2^11,^ ^129^ | 6.42 (1.13, 29.09) | 2^11,^ ^129^ | 1.10 (0.61, 1.98) | 3^11,^ ^33,^ ^129^ | 10.25 (4.21, 22.86)
General Population | 1^33^ | 4.34 | 1^33^ | 4.34 | 1^33^ | 8.68 (7.43, 10.11)

* Average risk = no first degree relatives with breast or ovarian cancer; moderate risk = one first degree relative with cancer or Ashkenazi Jewish without a first degree relative with cancer; high risk = two or more first degree relatives with cancer or Ashkenazi Jewish with one or more first degree relatives with breast or ovarian cancer.

† Sensitivity analysis.

‡ Results are obtained from Myriad Genetic Laboratories website and personal communications.

#### Ashkenazi Jewish Population

For the Ashkenazi Jewish population unselected by family history, five studies provided data about prevalence of BRCA1 mutations,^11,^ ^12,^ ^125^–^127^ six for BRCA2 mutations, ^11,^ ^12,^ ^125^–^128^ and four for mutations in the two genes combined.^11,^ ^12,^ ^125,^ ^127^ Results of the meta-analysis indicate an estimated prevalence of founder mutations of 1.9% (95% CI, 1.3%–2.8%), including 0.8% (0.5%–1.3%) BRCA1 and 1.1% (0.9%–1.4%) BRCA2 (Table 5).

For Ashkenazi Jews with a family history of breast or ovarian cancer, two studies provided prevalence data about BRCA1 mutations,^11,^ ^129^ two for BRCA2 mutations,^11,^ ^129^ and three for mutations in the two genes combined.^11,^ ^33,^ ^129^ Results of the meta-analysis indicated an estimated prevalence of founder mutations of 10.2% (4.2%–22.9%) including 6.4% (1.1%–29.1%) BRCA1 and 1.1% (0.6%–2.0%) BRCA2 (Table 5).

### Penetrance

Penetrance is the probability of developing breast or ovarian cancer among women who have a clinically significant BRCA1 or BRCA2 mutation. Published reports of penetrance describe estimates of BRCA1 and BRCA2 mutations ranging from 35% to 84% for breast cancer and 10% to 50% for ovarian cancer, calculated to age 70 years, for non-Ashkenazi Jewish women or those unselected for ethnicity.^21,^ ^27,^ ^28,^ ^130^–^133^ Among Ashkenazi Jewish women, penetrance estimates range from 26% to 81% for breast cancer and 10% to 46% for ovarian cancer.^11,^ ^125,^ ^134^–^138^

#### Limitations and Biases of Studies

Breast and ovarian cancer risk estimates are higher for relatives of women with breast cancer diagnosed at younger ages,^130^ and for women from families with a greater number of affected relatives.^21,^ ^131^ Penetrance estimates are highest when based on data from families selected for breast or ovarian cancer—the selection approach used for genetic linkage studies and for clinical referrals. In addition to family history of cancer, penetrance may be influenced by the mutation's location with the gene.^133,^ ^139^ Most studies do not have sufficient data to assess such heterogeneity.

For many published studies, penetrance was estimated from families without the benefit of genetic testing of all family members.^21,^ ^27,^ ^28,^ ^130^–^135,^ ^137^ Studies used genetic segregation analysis in which the probability of having a clinically significant BRCA1 and BRCA2 mutation is estimated for each relative of an individual who has an identified mutation. Penetrance is estimated from the occurrence of breast or ovarian cancer and the a priori mutation carrier probability for each relative. Such estimates are typically based on family members of women who have breast or ovarian cancer (probands). Even when unselected for family history of breast and/or ovarian cancer, estimates from this study design can result in biased estimates of penetrance because the probands, and thus their family members, are more likely to have other risk factors for breast cancer that may affect penetrance.^140^

Many studies focus on women with existing breast and ovarian cancer, introducing bias, since breast or ovarian cancer survivors may have different mutation frequencies compared with women with newly diagnosed cancer. Also, mutations are underestimated by most research studies because they employ a 2-step process in testing. This involves an initial test to detect clinically significant mutations followed by direct DNA sequencing for positive specimens only, rather than complete DNA sequencing of all specimens.

#### Meta-analysis-General Population

The probabilities of having a mutation if breast or ovarian cancer is present were combined with mutation prevalence among women without cancer, and a range of estimates of breast and ovarian cancer risk in average-, moderate-, and high-risk groups to estimate penetrance in the general population. (Methods are described in Appendix D.)

Breast cancer penetrance. Nine studies provided data of the probability of a mutation if breast or ovarian cancer is present for women at average risk,^27,^ ^29,^ ^36,^ ^132,^ ^141^–^145^ five studies for moderate risk,^27,^ ^29,^ ^142^–^144^ and six for high risk.^28,^ ^33,^ ^36,^ ^141,^ ^144,^ ^146^ Breast cancer penetrance estimates to ages 40 and 75, respectively, for clinically significant BRCA1 and BRCA2 mutations were 8.5% (6.7%–10.6%) and 31.6% (20.4%–45.4%) in average-risk, 3.4% (2.0%–5.5%) and 19.0% (1.0%–32.6%) in moderate-risk, and 7.7% (6.5%–9.1%) and 59.1% (44.4%–72.3%) in high-risk groups (Table 6).

Table 6 Results of Meta-Analysis of Penetrance Studies of Breast Cancer

Risk for mutation* | Age to develop cancer | BRCA1 | | BRCA2 | | BRCA1 or BRCA2
| | No. studies | Penetrance (%, 95% CI) | No. studies | Penetrance (%, 95% CI) | No. studies | Penetrance(%, 95% CI)
Average risk ^†^
Includes patients without family history | 40 | 4^29,^ ^141^–^143^ | 8.10^††^ (5.29, 12.21) | 2^29,^ ^143^ | 7.48^††^ (4.60, 11.96) | 2^29,^ ^143^ | 7.57^††^ (5.43, 10.47)
PBRCA1= PBRCA2 = 0.12% | 75 | 1^144^ | 52.18^††^ (31.34, 72.29) | 0 | No data | 1^#,^ ^27^ | 31.57^††^ (20.40, 45.37)
Includes patients without family history | 40 | 4^29,^ ^141^–^143^ | 10.51^††^ (6.93, 15.65) | 2^29,^ ^143^ | 9.74^††^ (6.04, 15.33) | 2^29,^ ^143^ | 9.85^††^ (7.11, 13.49)
PBRCA1= PBRCA2 = 0.09% | 75 | 1^144^ | 59.27^††^ (37.84, 77.67) | 0 | No data | 1^#,^ ^27^ | 38.09^††^ (25.46, 52.55)
Includes patients without family history | 40 | 4^29,^ ^141^–^143^ | 14.98^††^ (10.04, 21.77) | 2^29,^ ^143^ | 13.93^††^ (9.79, 21.36) | 2^29,^ ^143^ | 14.09^††^ (10.30, 18.96)
PBRCA1= PBRCA2 = 0.06% | 75 | 1^144^ | 68.58^††^ (47.73, 83.91) | 0 | No data | 1^#,^ ^27^ | 47.99^††^ (33.88, 62.42)
Includes patients without family history | 40 | 4^29,^ ^141^–^143^ | 26.06^††^ (18.25, 35.75) | 2^29,^ ^143^ | 24.44^††^ (16.16, 35.20) | 2^29,^ ^143^ | 24.67^††^ (18.68, 31.87)
PBRCA1= PBRCA2 = 0.03% | 75 | 1^144^ | 81.36^††^ (64.61, 91.25) | 0 | No data | 1^#,^ ^27^ | 64.86^††^ (50.62, 76.87)
Includes patients both selected for family history and without family history | 40 | 7^27,^ ^29,^ ^36,^ ^132,^ ^141^–^143^ | 9.60 ^††^ (4.80, 18.31) | 4^27,^ ^29,^ ^132,^ ^143^ | 7.38^††^ (5.33, 10.15) | 4^27,^ ^29,^ ^132,^ ^143^ | 7.15^††^ (5.67, 8.98)
PBRCA1= PBRCA2 = 0.12% | 75 | 2^142,^ ^143^ | 54.10^††^ (37.19, 70.12) | 0 | No data | 1^#,^ ^27^ | 31.57^††^ (20.40, 45.37)
Includes patients both selected for family history and without family history | 40 | 7^27,^ ^29,^ ^36,^ ^132,^ ^141^–^143^ | 12.41 ^††^ (6.29, 23.01) | 4^27,^ ^29,^ ^132,^ ^143^ | 9.61^††^ (6.98, 13.09) | 4^27,^ ^29,^ ^132,^ ^143^ | 9.31^††^ (7.42, 11.63)
PBRCA1= PBRCA2 = 0.09% | 75 | 2^142,^ ^143^ | 61.11^††^ (44.11, 75.78) | 0 | No data | 1^#,^ ^27^ | 38.09^††^ (25.46, 52.55)
Includes patients both selected for family history and without family history | 40 | 7^27,^ ^29,^ ^36,^ ^132,^ ^141^–^143^ | 17.52 ^††^ (9.15, 30.95) | 4^27,^ ^29,^ ^132,^ ^143^ | 13.75^††^ (10.12, 18.42) | 4^27,^ ^29,^ ^132,^ ^143^ | 13.35^††^ (10.73, 16.48)
PBRCA1= PBRCA2 = 0.06% | 75 | 2^142,^ ^143^ | 70.21^††^ (54.21, 82.44) | 0 | No data | 1^#,^ ^27^ | 47.99^††^ (33.88, 62.42)
Includes studies of patients selected for family history and unselected patients | 40 | 7^27,^ ^29,^ ^36,^ ^132,^ ^141^–^143^ | 29.82 ^††^ (16.77, 47.27) | 4^27,^ ^29,^ ^132,^ ^143^ | 24.18^††^(18.67, 31.11) | 4^27,^ ^29,^ ^132,^ ^143^ | 23.55^††^ (19.39, 28.30)
PBRCA1= PBRCA2 = 0.03% | 75 | 2^144,^ ^145^ | 82.50^††^ (70.31, 90.37) | 0 | No data | 1^#,^ ^27^ | 64.86^††^ (50.62, 76.87)
Moderate risk
General Population^†^ | 40**, ^‡‡^ | 5^29,^ ^94,^ ^141,^ ^142^ | 48.71^††^ (25.89, 72.07) | 3^94,^ ^142^ | 36.50^††^ (26.50, 47.81) | 4^29,^ ^94,^ ^142^ | 41.21^††^ (21.27, 64.53)
PBRCA1= PBRCA2 = 0.12% | 75 | 1^143^ | 86.15^††^ (70.35, 94.22) | 0 | No data | 1^#,^ ^4^ | 76.83^††^ (61.56, 87.28)
General Population^†^ | 40 **, ^‡‡^ | 5^29,^ ^94,^ ^141,^ ^142^ | 18.56^††^ (7.74, 38.25) | 3^94,^ ^142^ | 12.12^††^ (7.96, 18.03) | 4^29,^ ^94,^ ^142^ | 14.40^††^ (6.09, 30.39)
PBRCA1= PBRCA2 = 0.5% | 75 | 1^143^ | 59.88^††^ (36.29, 79.64) | 0 | No data | 1^#,^ ^4^ | 44.31^††^ (27.77, 62.22)
General Population^†^ | 40 **, ^‡‡^ | 5^29,^ ^94,^ ^141,^ ^142^ | 13.19^††^ (5.29, 29.23) | 3^94,^ ^142^ | 8.42^††^ (5.45, 12.79) | 4^29,^ ^94,^ ^142^ | 10.09^††^ (4.14, 22.54)
PBRCA1= PBRCA2 = 0.75% | 75 | 1^143^ | 49.88^††^ (27.52, 72.29) | 0 | No data | 1^#,^ ^4^ | 34.66^††^ (20.40, 52.33)
General Population^†^ | 40 **, ^‡‡^ | 5^29,^ ^94,^ ^141,^ ^142^ | 10.23^††^ (4.02, 23.65) | 3^94,^ ^142^ | 6.45^††^ (4.15, 9.91) | 4^29,^ ^94,^ ^142^ | 7.76^††^ (3.14, 17.92)
PBRCA1= PBRCA2 = 1%
Moderate risk
PBRCA1= PBRCA2 = 1% | 75 | 1^143^ | 42.74^††^ (22.17, 66.17) | 0 | No data | 1^#,^ ^4^ | 28.46^††^ (16.12, 45.16)
General Population^‡^ | 40**,^‡‡^ | 5^29,^ ^94,^ ^141,^ ^142^ | 6.28^††^ (2.41, 15.41) | 3^94,^ ^142^ | 3.90^††^ (2.48, 6.07) | 4^29,^ ^94,^ ^142^ | 4.72^††^ (1.87, 11.38)
PBRCA1= PBRCA2 = 1.7% | 75 | | 30.51 ^††^ (14.35, 53.50) | | | | 18.96^††^ (1.02, 32.63)
General Population^‡^ | 40**,^‡‡^ | 5^29,^ ^94,^ ^141,^ ^142^ | 8.06^††^ (3.12, 19.24) | 3^94,^ ^142^ | 3.17^††^ (2.02, 4.98) | 4^29,^ ^94,^ ^142^ | 4.72^††^ (1.87, 11.38)
PBRCA1= 1.3% PBRCA2 = 2.1% | 75 | 1^143^ | 36.47 ^††^ (17.97, 60.08) | 0 | No data | 1^#,^ ^27^ | 18.96^††^ (1.02, 32.63)
Ashkenazi Jewish | 40 | 2^150,^ ^151^ | 5.03 (1.85, 12.97) | 1^151^ | 1.23 (0.40, 3.75) | 3^86,^ ^151,^ ^153^ | 2.9 (1.55, 5.36)
Includes patients without family history | 75 | 3^134,^ ^138,^ ^152^ | 38.83 (27.26, 51.80) | 3^134,^ ^138,^ ^152^ | 24.89 (13.11, 42.14) | 5^86,^ ^125,^ ^134,^ ^138,^ ^152^ | 30.39 (22.20, 40.04)
Ashkenazi Jewish | 40 | 7^134,^ ^150^–^153^ | 9.55 (5.46, 16.18) | 5^134,^ ^137,^ ^150,^ ^152^ | 2.72 (1.62, 4.51) | 8^82,^ ^133,^ ^136,^ ^149^–^151^ | 5.02 (3.01, 8.26)
Includes patients both selected for family history and without family history | 75 | 7^134,^ ^137,^ ^138,^ ^144,^ ^152^ | 41.42 (27.80, 56.49) | 6^134,^ ^137,^ ^138,^ ^152^ | 24.17 (17.20, 32.84) | 6^141,^ ^142^ | 33.7 (24.10, 44.85)
High risk
General Population | 40 | 2^36,^ ^140^ | 11.29^††^ (7.75, 16.16) | 0 | No data | 1^33^ | 7.7 (6.49, 9.11)
| 75^##^ | 4^36,^ ^129,^ ^140,^ ^143^ | 60.53^††^ (52.34, 68.17) | 1^129^ | 53.00 ^††^ (42.20, 63.52) | 3^33,^ ^129,^ ^145^ | 59.07 (44.35, 72.32)
High risk
Ashkenazi Jewish | 40^‡‡^ | 3^129,^ ^150,^ ^151^ | 6.88 (1.92, 21.78) | 2^129,^ ^151^ | 9.1 (4.11, 18.94) | 5^33,^ ^86,^ ^128,^ ^146,^ ^153^ | 4.91 (1.93, 11.95)
| 75 | 3^129,^ ^134,^ ^152^ | 44.14 (11.47, 82.82) | 3^129,^ ^134,^ ^152^ | 57.44 (40.38, 72.89) | 6^33,^ ^86,^ ^125,^ ^128,^ ^151,^ ^153^ | 34.73 (17.60, 57.00)

* Average risk = no first degree relatives with breast or ovarian cancer; moderate risk = one first degree relative with cancer or Ashkenazi Jewish without a first degree relative with cancer; high risk = two or more first degree relatives with cancer or Ashkenazi Jewish with one or more first degree relatives with breast or ovarian cancer.

† The prevalence of BRCA1 and BRCA2 is assumed to be 0.12% in the unaffected population thus either BRCA1 or BRCA2 is 0.24%.

‡ The prevalence of BRCA1 and BRCA2 is assumed to be 1.7% in the unaffected population and either BRCA1 or BRCA2 is 3.4%.

§ The prevalence of BRCA1 and BRCA2 is assumed to be 4.34% in the unaffected population.

║ The analysis includes 1 study with data < 45 yrs, two studies < 35 yrs.

¶ The analysis includes 2 study with data < 45 yrs, two studies < 35 yrs.

# The analysis includes data from one study with population of < 55 yrs thus the penetrance of mutation is the probability of developing cancer by 55 yrs.

** Only one study has data directly on <40 yrs group. The analysis also includes 2 studies with data < 45 ys, two studies < 35 yrs

†† Prevalence of mutation from the control group is assumed to be fixed. The 95% CI of penetrance is narrower than it should be.

‡‡ Assuming the risk ratio is 2.53 by Collaborative Group on Hormonal Factors in Breast Cancer (CGHFBC), 2001,^85^ which is the risk ratio for family history with one first-degree relative for the group of patients diagnosed between 35–39.

§§ Assuming the risk ratio is 1.8 by CGHFBC, 2001, which is the overall risk ratio for family history with one first-degree relative.

║║ Assuming the risk ratio is 2.1 by Pharoah et al, 1997,^8^ which is the risk ratio for family history with at least one first-degree relative.

¶¶ Assuming the risk ratio is 5.26, by CGHFBC, 2001, which is the risk ratio for family history with two first-degree relatives for the group of patients diagnosed <35.

## Assuming the risk ratio is 2.93, by CGHFBC, 2001, which is the overall risk ratio for family history with two first-degree relatives.

Ovarian cancer penetrance. Three studies provided data of the probability of having a mutation if breast or ovarian cancer is present for women at average risk,^133,^ ^147,^ ^148^ three for moderate risk,^133,^ ^144,^ ^147^ and three for high risk.^33,^ ^141,^ ^149^ Ovarian cancer penetrance estimates to ages 50 and 75 were 13.0% (9.6%–17.4%) and 19.3% (13.7%–26.4%) in average-risk, no data for age 50 and 18.6% (14.0%–24.3%) in moderate-risk, and 4.0% (3.1%–5.2%) and 15.6% (12.9%–18.9%) in high-risk groups (Table 7).

Table 7 Results of Meta-Analysis of Penetrance Studies of Ovarian Cancer

Risk for mutation* | Age to develop cancer | BRCA1 | | BRCA2 | | BRCA1 or BRCA2
| | No. studies | Penetrance (%, 95% CI) | No. studies | Penetrance (%, 95% CI) | No. studies | Penetrance (%, 95% CI)
Average risk
Includes patients without family history | 50 | 0 | No Data | 0 | No Data | 0 | No Data
PBRCA1= PBRCA2 = 0.12% | <75^†^ | 2 ^#,^ ^133^ | 17.10 (11.27, 25.10) | 1^133^ | 20.64 (12.95, 31.27) | 1^133,^ ^147^ | 19.25 (13.68, 26.40)
Includes patients without family history | 50 | 0 | No Data | 0 | No Data | 0 | No Data
PBRCA1= PBRCA2 = 0.09% | <75^†^ | 2 ^#,^ ^133^ | 21.58 (14.48, 30.89) | 1^133^ | 25.75 (16.55, 37.76) | 1^133,^ ^147^ | 24.12 (17.44, 32.36)
Includes patients without family history | 50 | 0 | No Data | 0 | No Data | 0 | No Data
PBRCA1= PBRCA2 = 0.06% | <75^†^ | 2 ^#,^ ^133^ | 29.21 (20.25, 40.13) | 1^133^ | 34.22 (22.93, 47.64) | 1^133,^ ^147^ | 32.29 (24.06, 41.78)
Includes patients without family history | 50 | 0 | No Data | 0 | No Data | 0 | No Data
PBRCA1= PBRCA2 = 0.03% | <75^†^ | 2 ^#,^ ^133^ | 45.21 (33.68, 57.29) | 1^133^ | 50.99 (37.30, 64.54) | 1^133,^ ^147^ | 48.82 (38.79, 58.94)
Includes patients both selected for family history and without family history | 50 | 1^133^ | 19.82 (14.48, 26.53) | 1^133^ | 4.90 (2.12, 10.92) | 1^133^ | 13.00 (9.61, 17.35)
PBRCA1= PBRCA2 = 0.12% | <75^†^ | 3 ^#,^ ^133^ | 17.09 (11.54, 24.56) | 1^133^ | 20.64 (12.95, 31.27) | 1^133,^ ^147,^ ^148^ | 19.25 (13.68, 26.40)
Includes patients both selected for family history and without family history | 50 | 1^133^ | 24.79 (18.42, 32.50) | 1^133^ | 6.42 (2.81, 14.05) | 1^133^ | 16.61 (12.41, 21.87)
PBRCA1= PBRCA2 = 0.09% | <75^†^ | 3 ^#,^ ^133^ | 21.55 (14.81, 30.27) | 1^133^ | 25.75 (16.55, 37.76) | 1^133,^ ^147,^ ^148^ | 24.12 (17.44, 32.36)
Includes patients both selected for family history and without family history | 50 | 1^132^ | 33.09 (25.29, 41.94) | 1^133^ | 9.34 (4.15, 19.69) | 1^133^ | 23.00 (17.53, 29.57)
PBRCA1= PBRCA2 = 0.06% | <75^†^ | 3 ^#,^ ^133^ | 29.18 (20.68, 39.44) | 1^133^ | 34.22 (22.93, 47.64) | 1^133,^ ^147,^ ^148^ | 32.29 (24.06, 41.78)
Includes patients both selected for family history and without family history | 50 | 1^133^ | 49.72 (40.38, 59.09) | 1^133^ | 17.08 (7.97, 32.90) | 1^133^ | 37.4 (29.83, 45.65)
PBRCA1= PBRCA2 = 0.03% | <75^†^ | 3 ^#,^ ^133^ | 45.18 (34.28, 56.57) | 1^133^ | 50.99 (37.30, 64.54) | 1^133,^ ^147,^ ^148^ | 48.82 (38.79, 58.94)
Moderate risk
General Population | 50 | 0 | No Data | 0 | No Data | 0 | No Data
PBRCA1= PBRCA2 = 0.12% | <75^†^ | 4^#,^ ^94,^ ^133,^ ^143,^ ^147^ | 88.44 (85.43, 90.90) | 2^94,^ ^133^ | 69.83 (56.66, 80.36) | 2^94,^ ^133^ | 83.60 (67.61, 92.56)
General Population | 50 | 0 | No Data | 0 | No Data | 0 | No Data
PBRCA1= PBRCA2 = 0.5% | <75^‡^ | 4^#,^ ^94,^ ^133,^ ^143,^ ^147^ | 64.75 (58.46, 70.56) | 2^94,^ ^133^ | 35.71 (23.88, 49.59) | 2^94,^ ^133^ | 55.03 (33.38, 74.92)
General Population | 50 | 0 | No Data | 0 | No Data | 0 | No Data
PBRCA1= PBRCA2 = 0.75% | <75^‡^ | 4^#,^ ^94,^ ^133,^ ^143,^ ^147^ | 55.05 (48.41, 61.51) | 2^94,^ ^133^ | 27.03 (17.30, 39.60) | 2^94,^ ^133^ | 44.92 (25.04, 66.58)
General Population | 50 | 0 | No Data | 0 | No Data | 0 | No Data
Moderate risk
PBRCA1= PBRCA2 = 1% | <75^‡^ | 4^#,^ ^94,^ ^133,^ ^143,^ ^147^ | 47.87 (41.30, 54.52) | 2^94,^ ^133^ | 21.74 (13.56, 32.97) | 2^94,^ ^133^ | 37.96 (20.03, 59.90)
General Population | 50 | 0 | No Data | 0 | No Data | 0 | No Data
PBRCA1= PBRCA2 = 1.7% | <75^‡^ | 4^#,^ ^94,^ ^133,^ ^143,^ ^147^ | 35.07 (29.27, 41.35) | 2^94,^ ^133^ | 14.04 (8.45, 22.44) | 2^94,^ ^133^ | 26.46 (12.84, 46.77)
General Population | 50 | 0 | No Data | 0 | No Data | 0 | No Data
PBRCA1= 1.3% PBRCA2 = 2.1% | <75^‡^ | 4^#,^ ^94,^ ^133,^ ^143,^ ^147^ | 41.40 (35.12, 47.97) | 2^94,^ ^133^ | 11.68 (6.95, 18.97) | 2^94,^ ^133^ | 26.46 (12.84, 46.77)
Ashkenazi Jewish | 50 | 0 | No Data | 0 | No Data | 0 | No Data
Includes patients without family history | <75 | 0 | No Data | 0 | No Data | 1^135^ | 15.89 (10.46, 23.40)
Ashkenazi Jewish | 50 | 3^135,^ ^152,^ ^154^ | 14.16 (9.17, 21.23) | 3^135,^ ^152,^ ^154^ | 1.79 (0.88, 3.58) | 3^135,^ ^152,^ ^154^ | 7.50 (4.91, 11.30)
Includes patients both selected for family history and without family history | <75 | 5^127,^ ^133,^ ^135,^ ^152,^ ^154^ | 31.49 (21.91, 42.96) | 5^127,^ ^133,^ ^135,^ ^152,^ ^154^ | 11.72 (8.16, 16.56) | 5^127,^ ^133,^ ^135,^ ^152,^ ^154^ | 21.39 (14.9, 29.69)
High risk
General Population | 50 | 0 | No Data | 0 | No Data | 1^33^ | 4.03 (3.14, 5.16)
High risk
General Population | <75 | 2^141,^ ^149^ | 26.14 (21.98, 30.76) | 1^149^ | 6.43 (3.41, 11.82) | 2^33,^ ^149^ | 15.64 (12.88, 18.87)
Ashkenazi Jewish | 50 | 0 | No Data | 0 | No Data | 1^33^ | 3.31 (1.34, 7.92)
| <75 | 1^135^ | 21.67 (4.84, 60.07) | 1^135^ | 44.57 (28.06, 62.37) | 2^33,^ ^135^ | 18.11 (7.60, 37.30)
General Population** | 50 | 0 | No Data | 0 | No Data | 1^33^ | 13.99 (11.16, 17.40)
| <75 | 2^141,^ ^149^ | 60.17 (54.61, 65.48) | 1^149^ | 22.70 (13.09, 36.41) | 2^33,^ ^149^ | 44.19 (38.71, 49.82)

* Average risk = no first degree relatives with breast or ovarian cancer; moderate risk = one first degree relative with cancer or Ashkenazi Jewish without a first degree relative with cancer; high risk = two or more first degree relatives with cancer or Ashkenazi Jewish with one or more first degree relatives with breast or ovarian cancer.

† The prevalence of BRCA1 and BRCA2 is assumed to be 0.12% in the unaffected population thus either BRCA1 or BRCA2 is 0.24%.

‡ The prevalence of BRCA1 and BRCA2 is assumed to be 1.7% in the unaffected population and either BRCA1 or BRCA2 is 3.4%.

§ The prevalence of BRCA1 and BRCA2 is assumed to be 4.34% in the unaffected population.

║ In analysis of penetrance with family history (FH), the risk ratio of ovarian cancer with one relative is 3.1 by Stratton et al, 1998.^90^ No RR (relative risk) is available for FH with two first degree relatives. Penetrance might be underestimated for the group with two first-degree relatives. Ovarian cancer prevalence in Ashkenazi Jews is assumed to be the same as white.

¶ Prevalence of mutation from the control group is assumed to be fixed. The 95% CI of penetrance is narrower than it should be.

# The analysis includes 1 study with data < 70 yrs.

** In analysis of penetrance with FH, the risk ratio of ovariance cancer with more than one relative (either first or second) is 11.7 by Stratton et al, 1998.^90^ No RR is available for FH with two first degree relatives.

These penetrance estimates are similar to those published for a combined analysis of 22 studies based on case series data from women unselected for cancer family history.^130^ Breast and ovarian cancer risk estimates to age 70 years for women who have a BRCA1 mutation were 65% (44%–78%) and 39% (18%–54%), respectively; for BRCA2 mutation carriers, estimated breast and ovarian cancer risks were 45% (31%–56%) and 11% (2%–19%), respectively.

#### Meta-analysis-Ashkenazi Jewish Population

Breast cancer penetrance. Ten studies provided data of the probability of having a mutation if breast or ovarian cancer is present for Ashkenazi Jewish women without a family history,^86,^ ^125,^ ^134,^ ^137,^ ^138,^ ^144,^ ^150^–^153^ and nine for those with a family history.^33,^ ^86,^ ^125,^ ^128,^ ^134,^ ^150^–^153^ Among Ashkenazi Jewish women without a family history of breast or ovarian cancer, penetrance estimates to ages 40 and 75 were 5.0% (3.0%–8.3%) and 33.7% (24.1%–44.9%) (Table 6). For those with a family history, penetrance estimates to ages 40 and 75 were 4.9% (1.9%–12.0%) and 34.7% (17.6%–57.0%) (Table 6).

Ovarian cancer penetrance. Five studies provided data to determine ovarian cancer penetrance for women without a family history,^127,^ ^133,^ ^135,^ ^152,^ ^154^ and two for those with a family history.^33,^ ^135^ Among Ashkenazi Jewish women without a family history of breast or ovarian cancer, penetrance estimates to ages 50 and 75 were 7.5% (4.9%–11.3%) and 21.4% (14.9%–29.7%) (Table 7). For those with family history, penetrance estimates to ages 50 and 75 were 3.3% (1.3%–7.9%) and 18.1% (7.6%–37.3%) (Table 7). These penetrance estimates are consistent with those published in individual studies of Ashkenazi Jewish women.

## Key Question 4. What are the adverse effects of risk assessment, counseling, and testing?

Adverse effects of risk assessment, including genetic counseling, and testing include the potential for false positive and false negative results at each step of the process leading to false reassurance or inappropriate interventions. No studies directly addressed these issues. However, several studies described potential emotional distress.

A total of 57 studies, including 10 randomized controlled trials and 47 observational studies, were identified as relevant. Of these, 40 studies using non-standardized measures were excluded from further analysis. Nine fair to good quality studies assessing emotional distress were included (Appendixes M and N), and results are summarized in Table 8.^155^–^163^ Eight poor-quality studies were excluded because of high or differential loss to follow-up, attrition, contamination, failure to consider important outcomes, lack of adjustment for potential confounders, or poorly defined interventions.^164^–^171^

Table 8 Distress Due to Adverse Effects of Risk Assessment and Testing

Author, year | Study design | N | History of cancer | Genetic counseling | Measures of distress | Breast cancer worry | | | | Anxiety | | | | Depression | | | | Quality rating
| | | | | | First follow-up^†^ | | Final follow-up^‡^ | | First follow-up^†^ | | Final follow-up^‡^ | | First follow-up^†^ | | Final follow-up^‡^
| | | | | | Increase | Decrease | Increase | Decrease | Increase | Decrease | Increase | Decrease | Increase | Decrease | Increase | Decrease
Risk Assessment
Brain et al, 2002*^,^ ^156^ | RCT | 740 | Family | Clinical Geneticist or Genetic Nurse Specialist | BCWS, STAI, NSI | 0 | X | NR | NR | 0 | 0 | NR | NR | NR | NR | NR | NR | Good
Watson et al, 1999*^,^ ^163^ | Pre-Post | 303 | Family | Unknown | BCWS, GHQ, IES, STAI, NSI | 0 | 0 | 0 | 0 | 0 | X | 0 | 0 | 0 | 0 | 0 | 0 | Good
Hopwood et al, 1998*^,^ ^158^ | Non-comparative | 174 | Family | Unknown | GHQ, NSI | NR | NR | NR | NR | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | Good/Fair
Lobb et al, 2004*^,^ ^160^ | Longitudinal | 158 | Family or Personal | Clinical Geneticist or Oncologist or Genetic Counselor | HADS, IES, NSI | X | 0 | NR | NR | 0 | X | NR | NR | 0 | X | NR | NR | Good
Risk Assessment and Testing
Friedman et al, 1999^157^ | Prospective Cohort | 333 | Family, Personal, or None | Genetic Counselor | IES, POMS-SF, NSI | 0 | X | 0 | X^#^ | 0 | X | 0 | X | NR | NR | NR | NR | Fair
Meiser et al, 2002^†,^ ^161^ | Prospective Cohort | 143 | Family | Unknown | BDI, IES, MBSS, STAI, NSI | X** | 0 | X** | 0 | 0 | X^††^ | 0 | X** | 0 | X^††^ | 0 | 0 | Good
Testing
Smith et al, 1999^162^ | Prospective Cohort | 500 | Family | Genetic Counselor | IES, NSI | NR | NR | NR | NR | X | 0 | NR | NR | NR | NR | NR | NR | Fair
Lerman et al, 1998^159^ | Prospective Cohort | 396 | Family or Personal | Physician | CES-D, IES | NR | NR | NR | NR | NR | NR | NR | NR | X^‡‡^ | X^††^ | X^‡‡^ | X^††^ | Fair
Bish et al, 2002*^ ,^ ^155^ | Case Series | 63 | Personal | Specialist or Genetic Counselor | BCWS, GHQ, HADS, IES, NSI | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | Fair

BCWS, Breast Cancer Worry Scale; BDI, Beck Depression Inventory; CES-D, Center for Epidemiologic Studies Depression Scale; GHQ, General Health Questionnaire (12-, 28-, or 30-item); HADS, Hospital Anxiety and Depression Scale; IES, Impact of Events Scale; MBSS, Miller Behavioural Style Scale; NSI, non-standardized instrument; POMS-SF, Profile of Moods State - Short Form; STAI, State-Trait Anxiety Inventory.

X, statistically significant relationship; 0, studied but not significant; NR, not reported.

* Study done in a country other than the United States (e.g. England, Wales, or Australia).

† First follow-up was immediate to 2 weeks: Bish et al, 2002; Brain et al, 2002; Smith et al, 1999; 4 weeks: Lobb et al, 2004; 1 month: Watson et al, 1999; Friedman et al, 1999; Lerman et al, 1998; 3 months: Hopwood et al, 1998; 4 months: Meiser et al, 2002.

‡ Final follow-up was 6 months for all studies except Hopwood, 1998 and Meiser, 2002, which were 12 months.

║ Low and moderate risk subjects only.

¶ Breast cancer worry not changed at final follow-up but perception of breast cancer worry as a problem was significantly reduced.

# Average risk subjects only.

** Mutation carriers only.

†† Non-carriers only.

‡‡ Subjects with high baseline distress who declined test result.

One randomized controlled trial^156^ and eight observational trials with pre-post,^163^ case series,^155^ longitudinal,^160^ prospective cohort,^157,^ ^159,^ ^161,^ ^162^ and non-comparative^158^ designs assessed breast cancer risk assessment, genetic testing, or both and their subsequent impact on distress measured as breast cancer worry, anxiety, or depression. All studies included genetic counseling. Studies varied in the number of distress indicators reported. Follow-up periods also varied; the first follow-up was defined as immediate to 2 weeks in three studies,^155,^ ^156,^ ^162^ 4 weeks in four studies,^157,^ ^159,^ ^160,^ ^163^ and 4 months in one study.^161^ Final follow-up was defined as 6 months for all studies but two.^158,^ ^161^

Overall, more studies showed decreased rather than increased distress indicators after risk assessment and testing (Table 8). However, generalizability is limited, and only two studies distinguished between mutation carriers and non-carriers.^159,^ ^161^

### Breast Cancer Worry

Two studies reported decreased breast cancer worry at the first follow-up evaluation,^156,^ ^157^ and one at both the first and final evaluations.^157^ These studies included women from high-risk breast cancer families,^156^ and a mixed group of women at average and high risk who tested negative for BRCA mutations.^157^ One study of women from high-risk breast cancer families showed increased breast cancer worry at first follow-up but had no additional follow-up data.^160^ Increased breast cancer worry for mutation carriers^161^ was seen at the final follow-up (12 months) in one study.^161^

### Anxiety

One study reported decreased anxiety for mutation carriers at the final 12-month follow-up evaluation, and decreased anxiety at the first 4-month follow-up for non-mutation carriers.^161^ A study of women in the largest known kindred identified with a deleterious BRCA1 mutation showed increased anxiety 1 to 2 weeks after testing, especially in carrier women who were tested first in their families and whose tested siblings were non-carriers.^162^ In contrast, three other studies of women with a family history of breast cancer,^157,^ ^160,^ ^163^ including women from high-risk families,^160^ showed decreased anxiety at the first 1-month follow-up evaluation, and one showed continued decreased anxiety at 6-month evaluation^157^

### Depression

Three studies with depression outcomes showed mixed results. Members of extended hereditary breast or ovarian cancer families, 27 with deleterious BRCA1 mutations and 6 with deleterious BRCA2 mutations, reported an increase in depression at the first and final follow-up evaluations for those who had cancer-related stress symptoms and declined testing, and a decrease in depression among non-carriers who were tested.^159^ Another study of women with family histories of breast or ovarian cancer showed decreased depression in non-carriers at the first 4-month follow-up.^161^ A study of women from high-risk families that did not distinguish impact on carriers vs. non-carriers found a decrease in depression after the first 1-month follow-up.^160^

### Differential Impact of Risk Assessment, Testing, or Both on Distress

Distress varied by whether studies evaluated risk assessment, genetic testing, or both. When risk assessment was evaluated in four studies, one showed an increase in breast cancer worry.^160^ There were no increases in other distress measures,^156,^ ^158,^ ^163^but decreases in breast cancer worry, ^156^ anxiety,^160,^ ^163^ and depression.^160^

When genetic testing was evaluated in three studies,^155,^ ^159,^ ^162^ results indicated no increased breast cancer worry, but in one study results indicated increased anxiety at the first follow-up evaluation ^162^ A study evaluating carriers and non-carriers showed increased depression at the first and final follow-up evaluations for those with high cancer-related stress who declined testing, and decreased depression for non-carriers who were tested.^159^

In the two studies including both risk assessment and genetic testing, results were mixed. One study showed increased breast cancer worry at both follow-up evaluations for mutation carriers,^161^ while the other, which evaluated only those who tested negative, showed decreased breast cancer worry.^157^ The first study showed decreased anxiety at the first follow-up for non-carriers and at the final follow-up for mutation carriers. It also showed decreased depression at the first follow-up for non-carriers.^161^ The second study showed decreased anxiety at first and final follow-up, and did not assess depression.^157^

## Key Question 5. How well do interventions reduce the incidence and mortality of breast and ovarian cancer in women identified as high-risk by history, positive genetic test results, or both?

### Intensive Screening

#### Breast Cancer

Intensive screening for breast cancer in BRCA mutation carriers is recommended by expert groups,^172^ and is based on favorable results of programs designed for women with familial risk (Table 9).^55,^ ^173^–^181^ However, there are no trials of the effectiveness of intensive screening for BRCA mutation carriers in reducing mortality. Recent descriptive studies report increased risks for interval cancers (those occurring between mammograms) in BRCA mutation carriers with and without prior cancer undergoing annual mammographic screening.^70,^ ^173,^ ^182,^ ^183^ These data imply that yearly mammograms may miss highly proliferate cancers that are more common in BRCA mutation carriers.^184^–^186^

Table 9 Intensive Screening Studies in Women With Familial Breast Cancer Risk*

Author, year | No. of women (total/BRCA mutation carriers) | Inclusion criteria | Mean age at entry in years (range) | Screening method | Screening interval | Mean follow-up | Detection rate^†^ per 1000 | Sensitivity (%)
Brekelmans et al, 2001^173^ | 1198/128 | FH+: RR > 2 | 38 (21–70) | Mam + CBE + MRI^‡^ | 6-monthly CBE + annual Mam + MRI^‡^ | 36 months | 8.6 | 74
Chart and Franssen, 1997^174^ | 1044/UN | FH+ or combination of other risk factors | 39.5/42.7 (2 populations) | Mam + CBE | Annual (high risk: 6-monthly CBE) | 21.9 months | 7.3 | 91
Gui et al, 2001^175^ | 1078/UN | FH+: lifetime risk > 1 in 6 | 45 (26–66) | Mam + CBE | Annual | UN | 4.4 | N/A
Kollias et al, 1998^176^ | 1371/UN | FH+: lifetime risk > 1 in 9 | 41 (18–49) | Mam + CBE | Annual CBE + biennial Mam | 22 months | 9.1 | 66
Komenaka et al, 2004^182^ | UN/13 | BRCA mutation carrier | 46 (32–59) | Mam | Annual | UN | 3 | N/A
Lai et al, 1998^177^ | 2629/UN | Relative of case | UN (>35) | Mam + CBE | Annual | UN | 5.7 | UN
Lalloo et al, 1998^178^ | 1259/UN | FH+: lifetime risk > 1 in 6 | 39.1 (28–49) | Mam | Annual | 30 months | 5.5 | 87
Moller et al, 1996^179^ | 1194/UN | FH+ (see ref) | 42.9 | Mam | Annual | 1.8 years | 5.8 | UN
Saetersdal et al, 1996^180^ | 537/UN | Dominant inheritance | 42.5 (20–76) | Mam + CBE | 1st-round results | N/A | 15 | N/A
Scheuer et al, 2002^183^ | UN/165 | BRCA mutation carrier | 47.7 (24.1–79.0) | Mam + CBE + MRI^‡^ | 3–6 monthly CBE + annual Mam | 24.1 months (range 1.6–66.0) | 0.7 | N/A
Tilanus-Linthorst et al, 2000^181^ | 678/UN | > 15% lifetime risk | 42.9/43.3 (20–75) | Mam + MRI^‡^ + CBE | Annual (high risk: 6-monthly CBE) | 3.3 years | 9.3 | 92
Warner et al, 2004^55^ | 236/236 | BRCA mutation carrier | 46.6 (26.4–64.8) | Mam + MRI + Ultrasound + CBE | Annual with 6-month CBE | 100% round 1; 58% round 2, 36% round 3 | 22.6 | 95 (all modalities combined)

CBE, clinical breast examination; FH, family history; Mam, mammography; MRI, magnetic resonance imaging; RR, relative risk; UN, unknown.

* Adapted from Brekelmans et al, 2001^173^.

† For invasive breast cancers only.

‡ In selected cases (dense breast tissue or BRCA carrier).

In one study, high-risk women, including 113 BRCA1 and 15 BRCA2 mutation carriers without prior breast cancer, were followed in an intensive screening program at a family cancer clinic in the Netherlands that included monthly breast self-examination, twice-yearly clinical breast examinations, yearly mammography with MRI for those with dense breast tissue and/or BRCA gene mutations, and ultrasonography and fine-needle biopsy when indicated.^173^ Sensitivity of this approach for detecting breast cancer was 74% overall, but dropped to 56% for BRCA mutation carriers, and four of the nine breast cancer cases among mutation carriers were detected during the period between mammograms (44%).^173^

Additional studies of BRCA mutation carriers, including both women with and without previous breast cancer diagnoses, enrolled in similar programs also report high proportions of interval cancers. Four of 13 mutation carriers undergoing intensive screening at the Columbia-Presbyterian Comprehensive Breast Center in New York had breast cancer detected at the time of their annual mammograms, and 6 women had interval malignancies that presented as palpable masses from 2 to 9 months (mean 5 months) after the last mammogram (60%).^182^ A prospective study of BRCA carriers undergoing either preventive surgery or intensive screening reported that 6 of 12 mutation carriers who developed breast cancer while undergoing intensive screening were interval cases (50%).^183^

To improve detection of early breast cancer in BRCA mutation carriers, a comparison of four intensive screening modalities was conducted in 236 Canadian women with BRCA1 or BRCA2 mutations aged 25 to 65.^55^ Women underwent one to three annual screening examinations including MRI, mammography, and ultrasound with clinical breast examinations provided every 6 months. MRI was more sensitive for detecting breast cancers (sensitivity 77%, specificity 95.4%) than mammography (sensitivity 36%, specificity 99.8%), ultrasound (sensitivity 33%, specificity 96%), or clinical breast examination alone (sensitivity 9%, specificity 99.3%). Use of MRI, ultrasound, and mammography together had a sensitivity of 95%. Only one interval cancer was reported, and 14% of women had a biopsy that proved to be benign. MRI has advantages over mammography for detecting lesions in denser breast tissue and BRCA1-related cancers that have morphologic features suggesting a more benign mammographic image.

#### Ovarian Cancer

Data are limited regarding benefits of intensive screening strategies for ovarian cancer in BRCA mutation carriers. One study using transvaginal ultrasound to screen 1,610 women with a family history of ovarian cancer found 3.8% abnormal scans, and only 3 of 61 women with abnormal scans had ovarian cancer.^187^

### Chemoprevention

#### Selective Estrogen Receptor Modulators (SERMs)

Four randomized placebo-controlled prevention trials of tamoxifen, three rated fair to good quality^59^–^61^ and one rated fair quality,^62^ and one good quality trial of raloxifene^64^ with breast cancer incidence and mortality outcomes have been published (Appendixes O and P), and a trial comparing these agents is in progress.^65,^ ^188^ None of the trials specifically evaluated chemoprevention for women with BRCA mutations, although a genomic analysis of women developing breast cancer in one tamoxifen trial has been published.^189^ No trials of chemoprevention using SERMs for ovarian cancer have been published. All trials reported high loss to follow-up (60% to 96% at 60 months), and three trials reported more loss from treatment than placebo groups due to side effects.^59,^ ^61,^ ^64^

Three tamoxifen trials had inclusion criteria based on assessment of risk for breast cancer, including the Royal Marsden Hospital Trial, International Breast Cancer Intervention Study (IBIS-I), and National Surgical Adjuvant Breast and Bowel Project Breast Cancer Prevention Trial P-1 (BCPT P-1) (described in Appendix O).^59^–^61^ Two other trials did not assess subjects for breast cancer risk, and women in these studies could have lower risks of breast cancer than the general population. The Italian Tamoxifen Prevention Study included women who had had hysterectomies for benign conditions, with nearly half reporting previous bilateral oophorectomies, potentially reducing their risks for breast cancer.^62^ The Multiple Outcomes of Raloxifene Evaluation (MORE) study was primarily a fracture prevention trial that evaluated breast cancer as a secondary outcome, and included postmenopausal women with osteoporosis.^64^ Osteoporosis may be a marker for non-use of postmenopausal hormone therapy and low endogenous estrogen production lowering risk for breast cancer.^190,^ ^191^

All trials enrolled healthy women without previous breast cancer; measured incident breast cancer cases and deaths; were multicenter, double-blind, and placebo controlled; and used the same dose of tamoxifen (20 mg per day), except for MORE, which used raloxifene (60 or 120 mg per day). The smallest trial enrolled approximately 1,200 women in each arm of the study,^61^ and the largest enrolled over 6,500 in each arm.^60^ Mean follow-up ranged from 40 months in MORE to 70 months in the Royal Marsden Hospital Trial. Estrogen use during the study varied from 40% of women in IBIS-I, 26% in the Royal Marsden Hospital Trial, 14% in the Italian Tamoxifen Prevention Study, to 10% or less in the BCPT P-1 and MORE. Data were not provided to distinguish what proportion of estrogen users were using progestin as well.

For the two largest trials, tamoxifen significantly reduced the overall risk for breast cancer (Table 10).^59,^ ^60^ Tamoxifen reduced risk for users in all age groups, and reduced estrogen receptor-positive but not estrogen receptor-negative tumors.^59,^ ^60^ The Royal Marsden Hospital Trial and Italian Tamoxifen Prevention Study reported nonstatistically significant reductions in risk.^61,^ ^62^ The MORE trial reported significant reductions in risk among raloxifene users at both the 60 and 120 mg per day doses for total cases as well as invasive and estrogen receptor-positive cases (Table 10).^64^ These results persisted with an additional year of treatment and follow-up.^192^

Table 10 Results of Chemoprevention Trials

Study | Subjects | N | Median follow-up (mo) | Breast cancer cases
| | | | | Treatment | | Placebo | | Relative risk (95% CI)
| | | | | No. | Rate* | No. | Rate*
Tamoxifen (20 mg per day)
International Breast Cancer Intervention Study (IBIS-I) (IBIS, 2002)^59^ | Increased breast cancer risk based on family history and other factors. | 3573 tamoxifen | 50 | Total | 69 | | 101 | | 0.68 (0.50–0.92)
| Mean age 50.8 years; 40% using estrogen. | 3566 placebo | | Non-invasive | 5 | | 16 | | 0.31 (0.12–0.82)
| | | | Invasive | 64 | | 85 | | 0.75 (0.54–1.04)
| | | | ER positive | 44 | | 63 | | 0.69 (0.47–1.02)
| | | | ER negative | 19 | | 19 | | 1.00 (0.53–1.87)
| | | | Deaths | 2 | | 2 | | 1.00 (0.14–7.08)^†^
National Surgical Adjuvant Breast and Bowel Project P-1 Study (Fisher et al, 1998)^60^ | Increased breast cancer risk by Gail model, age ≥60 years, or risk factors. | 6576 tamoxifen | 55 | Total | 124 | | 244 | | 0.51 (0.41–0.63)^†^
| 39% <50 years old; <10% using estrogen. | 6599 placebo | | Non-invasive | 35 | 1.4 | 69 | 2.7 | 0.50 (0.33–0.77)
| | | | Invasive | 89 | 3.4 | 175 | 6.8 | 0.51 (0.39–0.66)
| | | | ER positive | 41 | | 130 | | 0.31 (0.22–0.45)
| | | | ER negative | | | | | NA
| | | | Deaths | 3 | | 6 | | 0.50 (0.13–2.01)^†^
Royal Marsden Hospital Trial (Powles et al, 1998)^61^ | Family history of breast cancer <50 years old or in ≥2 relatives. | 1238 tamoxifen | 70 | Total | 34 | 4.7 | 36 | 5.0 | 0.94 (0.59–1.49)^†^
| Median age 47 years; 26% using estrogen. | 1233 placebo | | Non-invasive | | | | | NA
| | | | Invasive | | | | | NA
| | | | ER positive | | | | | NA
| | | | ER negative | | | | | NA
| | | | Deaths | 4 | | 1 | | 3.98 (0.45–35.59)
Italian Tamoxifen Prevention Study (Veronesi et al, 1998)^62^ | Women with hysterectomy. | 2700 tamoxifen | 46 | Total | 19 | 2.1 | 22 | 2.3 | 0.87 (0.47–1.60)^†^
| Median age 51 years; 14% using estrogen. | 2708 placebo | | Non-invasive | | | | | NA
| | | | Invasive | | | | | NA
| | | | ER positive | 8 | | 10 | | 0.80 (0.32–2.03)^†^
| | | | ER negative | | | | | NA
| | | | Deaths | 0 | | 0 | | NS
Raloxifene (60 or 120 mg per day)
Multiple Outcomes of Raloxifene Evaluation (Cummings et al, 1999)^64^ | Postmenopausal women with osteoporosis. | 5129 raloxifene | 40 | Total | 22 | 1.5 | 32 | 4.3 | 0.35 (0.21–0.58)
| Median age 66.9 years; 10% on estrogen. | 2576 placebo | | Non-invasive | 7 | | 5 | | 0.70 (0.22–2.21)^†^
| | | | Invasive | 13 | 0.9 | 27 | 3.6 | 0.24 (0.13–0.44)
| | | | ER positive | 4 | | 20 | | 0.10 (0.04–0.24)
| | | | ER negative | 7 | | 4 | | 0.88 (0.26–3.0)
| | | | Deaths | 1 | | 0 | | NS

ER, estrogen receptor; NA, not available; NS, not statistically significant.

* Per 1,000 woman-years.

† Calculated.

Combining all trials in a meta-analysis resulted in a relative risk for total breast cancer of 0.62 (0.46–0.83) (Figure 3). Results were similar when including only the three tamoxifen trials that used family history of breast cancer as inclusion criteria, and when including the four tamoxifen trials only (Figure 3). Few deaths from breast cancer were reported in all the trials, and there were no differences between treatment and placebo groups. The relative risk was further reduced for estrogen receptor-positive breast cancer (4 trials; 0.39; 0.20–0.79) (Figure 4).

Figure 3. Relative Risk (RR) of Breast Cancer in Chemoprevention Trials

Figure 4. Relative Risk (RR) of Estrogen Receptor (ER) Positive Breast Cancer in Chemoprevention Trials

Treatment effects of tamoxifen could vary depending on the type of mutation. BRCA mutation status was determined in some women who developed breast cancer in BCPT P-1. Genomic analysis of 288 women indicated^189^ 6 of 7 cases with BRCA1 mutations were estrogen receptor-negative (86%), and 6 of 9 cases with BRCA2 mutations were estrogen receptor-positive (67%), consistent with known distributions.189 The point estimate for breast cancer for BRCA2, but not BRCA1, carriers using tamoxifen approximated that of the total population of tamoxifen users for estrogen receptor-positive tumors (RR 0.31; 0.22–0.45).^189^

#### Oral Contraceptives

No randomized controlled trials of oral contraceptives to prevent breast or ovarian cancer have been published. Observational studies indicate associations between oral contraceptives and reduced ovarian cancer in the general population^193^–^195^ as well as BRCA mutation carriers,^196^ but increased breast cancer among women with family histories of breast cancer.^197^

Breast cancer. A retrospective cohort study of families of breast cancer probands diagnosed between 1944 and 1952 at the University of Minnesota collected follow-up data on families 40 years later.^197^ Use of oral contraceptives was associated with a significantly increased risk of breast cancer among sisters and daughters of the probands (RR 3.3; 1.6–6.7), but not among granddaughters and nieces or non-blood relatives.^197^ Risk was highest for women using oral contraceptives prior to 1975, when higher dosages of estrogen and progestins were used. Small numbers of cases using oral contraceptives after 1975 and younger ages of granddaughters restrict these estimates.

A small study of women with breast cancer compared past oral contraceptive use of mutation carriers with non-carriers.^198^ Results indicated that more mutation carriers than non-carriers used oral contraceptives for more than 48 months before a first full-term pregnancy (OR 7.8; 1.1–55.0).^198^

Ovarian cancer. A case-control study of BRCA mutation carriers with ovarian cancer and their sisters without ovarian cancer (both mutation carriers and non-carriers) indicated reduced risk among those with any past use of oral contraceptives (OR 0.5; 0.3–0.8).^196^ Risk decreased with increasing duration of use and was protective for carriers of either BRCA1 or BRCA2 mutations.^196^ A population-based case-control study of ovarian cancer among BRCA1 and BRCA2 mutation carriers among Jewish women in Israel indicated that risk of ovarian cancer decreased with each birth, but not with increased duration of oral contraceptives.^127^ A study of risk factors for ovarian cancer included BRCA1 mutation carriers and non-carriers with ovarian cancer identified through registries compared with matched controls identified randomly in the San Francisco Bay Area.^199^ Results indicated associations between reduced risk for ovarian cancer and ever use of oral contraceptives, duration of oral contraceptive use, history of tubal ligation, and increasing parity. Risk reduction was similar between mutation carriers and non-carriers. Differences between results of studies may be due to discrepancies in populations, methods, and confounders, or chance and other factors.

### Prophylactic Surgery

No randomized controlled trials of prophylactic surgery have been conducted, and investigators acknowledge that this approach would not be ethical. Cohort studies of prophylactic surgery present several methodologic limitations to consider when interpreting their results.^200^

#### Biases Leading to Overestimation of Effect

For subjects selecting surgery, the course of events leading to surgery progresses in a sequence that can be easily captured in cohort studies, i.e., women obtain test results, make a decision about surgery, and then undergo the procedure. This course of events is less clear for women in nonsurgical comparison groups, particularly if they are not enrolled prospectively. Many of these women underwent testing after receiving a diagnosis of cancer. Risk reduction from surgery would be overestimated because the comparison group would be weighted with women with cancer.

This bias may be even more pronounced in studies enrolling women who are related to each other.^70,^ ^72^ A woman with cancer who then undergoes testing may be selected for the nonsurgical comparison group. In the meantime, she may have influenced her sister without cancer to undergo testing and surgery and become part of the intervention group. Subjects in the comparison group should be free of cancer at the point of follow-up in order to establish a similar baseline risk for both surgical and nonsurgical groups.

Women who choose prophylactic mastectomy may be more likely to also choose prophylactic oophorectomy^70,^ ^74^ and experience a cumulative reduction in risk for breast cancer that would be attributed to only the mastectomy. Prophylactic oophorectomy may act as both a confounder and an effect modifier for breast cancer.

Parity and young age at first birth are associated with decreased breast and ovarian cancer risk, and women who experienced childbirth at early ages and multiple times may have more benefit from prophylactic oophorectomy.^72^ Parous mutation carriers may be more likely to elect prophylactic oophorectomy and at younger ages than nonparous women. This could lead to an overestimate of effect. Similarly, other important confounders should also be considered, such as increased use of hormone therapy in women undergoing oophorectomy.^72,^ ^73^

#### Biases Leading to Underestimation of Effect

Selection of comparison groups is problematic because even if subjects are well matched on type of mutation, age, and other factors, it is currently not possible to match unrelated subjects on expected penetrance. Penetrance varies widely, and members of families with more cases of cancer, and likely higher prevalence and higher risk than the comparison group, may be more likely to choose prophylactic surgery for themselves.

Prophylactic surgery may reveal clinically undetected tumors. Studies that include this event in the surgery group could underestimate the efficacy of surgery for incidence outcomes, and overestimate it for mortality outcomes. Excluding these tumors entirely, however, would bias survival outcomes because the surgery may have increased life expectancy.

The type of prophylactic procedure could also influence outcomes. Patients undergoing mastectomy at times when subcutaneous mastectomies were performed, rather than total mastectomies, may have higher subsequent breast cancer rates because more residual breast cancer tissue remained after surgery than women undergoing total mastectomy. Most of the women in a retrospective study at the Mayo Clinic had subcutaneous mastectomies.^201^ Similarly, results from an oophorectomy could be less optimal than from a salpingo-oophorectomy or salpingo-oophorectomy with hysterectomy because of residual tissue at continued risk for cancer.

#### Bilateral Mastectomy

Four studies of prophylactic bilateral mastectomy in high-risk women have been published, including two retrospective cohort studies based on medical records at the Mayo Clinic,^201,^ ^202^ a prospective cohort study of mutation carriers in the Netherlands,^70^ and a study of mutation carriers with prospective and retrospective cohort data from multiple centers in North America and Europe^71^ (Appendix Q). Studies of mutation carriers ranged from 26 to 483 subjects and follow-up for 3 to 14 mean years postmastectomy. Study quality was fair for two studies,^70,^ ^202^ and two studies had designs that did not fit USPSTF criteria (Appendix R).^71,^ ^201^

Study results were consistent, indicating an 85% to 100% risk reduction for breast cancer, despite differences in study designs and comparison groups ranging from sisters,^201^ matched controls,^71^ a surveillance group,^70^ and penetrance models.^202^

#### Bilateral Oophorectomy

Four studies of prophylactic oophorectomy met inclusion criteria, including a retrospective study of families with members with breast and ovarian cancer,^203^ two retrospective cohort studies of mutation carriers undergoing oophorectomy compared with matched comparison groups in North America and Europe,^72,^ ^73^ and a prospective cohort study of mutation carriers undergoing elective oophorectomy or surveillance^74^ (Appendix Q). Average follow-up time in the retrospective studies was from 5 to 11 years and in the prospective study 2 years. Study quality was fair for the prospective study^74^ and the retrospective study of family members,^203^ and two studies had designs that did not fit USPSTF criteria (Appendix R).^72,^ ^73^

All studies reported reduced risks for ovarian and breast cancer with prophylactic oophorectomy, although numbers of cases were small and the confidence intervals for the only prospective study crossed 1.0 for both outcomes.^74^ Overall, the risk reduction for ovarian cancer ranged from 85% to 100%, and for breast cancer from 53% to 68%. One study found that oophorectomy after the age of 50 years was not associated with substantial breast cancer risk reduction,^72^ consistent with other studies of oophorectomy in the general population.^204^–^207^

#### Tubal Ligation

Tubal ligation has been associated with a decreased risk of invasive epithelial ovarian cancer in observational studies.^194,^ ^208,^ ^209^ A matched case-control study of mutation carriers with and without ovarian cancer indicated a reduced odds ratio among controls who underwent previous tubal ligation when adjusted for oral contraceptive use, parity, history of breast cancer, and ethnic group (OR 0.39; 0.22–0.70).^210^ This protective effect was present only among BRCA1 mutation carriers, although the number of BRCA2 carriers was small in this study.

## Key Question 6. What are the adverse effects of interventions?

### Intensive Screening

No studies were identified that describe the adverse effects of intensive screening for breast or ovarian cancer. Potential adverse effects include inconvenience of frequent examinations and procedures, exposure to ionizing radiation that could increase risk for breast cancer,^211^ cost, harms resulting from false positive findings and subsequent testing and biopsies, and false reassurance for women who may have increased risks for developing cancer between periodic screening tests.

### Chemoprevention

Several adverse effects were reported in the tamoxifen and raloxifene trials (Table 11). All trials indicated increased risk for thromboembolic events, including pulmonary embolism and deep vein thrombosis (5 trials; 2.21; 1.63–2.98; Figure 5).^59^–^62,^ ^64^ Three tamoxifen trials reported increased incidence of stroke, although there were few cases and the confidence intervals crossed 1.0 (1.50; 1.01–2.24; Figure 6).^59,^ ^60,^ ^62^ Three tamoxifen trials reported increased endometrial cancer (2.42; 1.46–4.03; Figure 7).^59^–^61^ All cause death was significantly increased for tamoxifen users in IBIS-I only (2.27; 1.12–4.60) (Figure 8).^59^

Table 11 Results of Chemoprevention Trials—Adverse Effects

Study | Subjects | N | Median follow-up (mo) | Adverse effects
| | | | | Treatment | | Placebo | | Relative risk (95% CI)
| | | | | No. | Rate* | No. | Rate*
Tamoxifen (20 mg per day)
International Breast Cancer Intervention Study (IBIS-I) (IBIS, 2002)^59^ | Increased breast cancer risk based on family history and other factors. | 3573 tamoxifen | 50 | Thromboembolic event | 43 | | 17 | | 2.5 (1.5–4.4)
| Mean age 50.8 years; 40% using estrogen. | 3566 placebo | | Pulmonary embolism | 13 | | 10 | | 1.30 (0.57–2.96)^†^
| | | | Deep vein thrombosis | 24 | | 5 | | 4.79 (1.83–12.54)^†^
| | | | Stroke | 13 | | 11 | | 1.18 (0.53–2.63)^†^
| | | | Endometrial cancer | 11 | | 5 | | 2.2 (0.8–6.06)
| | | | All cause death | 25 | | 11 | | 2.27 (1.12–4.60)^†^
National Surgical Adjuvant Breast and Bowel Project P-1 Study (Fisher et al, 1998)^60^ | Increased breast cancer risk by Gail model; age ≥60 years or risk factors. | 6576 tamoxifen | 55 | Thromboembolic event | 53 | NA | 28 | NA | 1.90 (1.20–3.00)^†^
| 39% <50 years old; <10% using estrogen. | 6599 placebo | | Pulmonary embolism | 18 | 0.69 | 6 | 0.23 | 3.01 (1.15–9.27)
| | | | Deep vein thrombosis | 35 | 1.34 | 22 | 0.84 | 1.60 (0.91–2.86)
| | | | Stroke | 38 | 1.45 | 24 | 0.92 | 1.59 (0.93–2.77)^†^
| | | | Endometrial cancer | 36 | 2.3 | 15 | 0.91 | 2.53 (1.35–4.97)
| | | | All cause death | 57 | 2.17 | 71 | 2.71 | 0.81 (0.56–1.16)^†^
Royal Marsden Hospital Trial (Powles et al, 1998)^61^ | Family history of breast cancer <50 years old or in ≥2 relatives. | 1238 tamoxifen | 70 | Thromboembolic event | 7 | | 4 | | 1.74 (0.51–5.94)^†^
| Median age 47 years; 26% using estrogen. | 1233 placebo | | Pulmonary embolism | 3 | | 2 | | 1.49 (0.25–8.93)^†^
| | | | Deep vein thrombosis | 4 | | 2 | | 1.99 (0.37–10.86)^†^
| | | | Stroke | | | | | NA
| | | | Endometrial cancer | 4 | | 1 | | 3.98 (0.46–35.59)^†^
| | | | All cause death | 9 | | 6 | | 1.49 (0.53–4.18)^†^
Italian Tamoxifen Prevention Study (Veronesi et al, 1998)^62^ | Women with hysterectomy. | 2700 tamoxifen | 46 | Thromboembolic event | 7 | | 4 | | 1.76 (0.51–5.99)^†^
| Median age 51 years; 14% using estrogen. | 2708 placebo | | Pulmonary embolism | 1 | | 1 | | 1.00 (0.06–16.03)^†^
| | | | Deep vein thrombosis | 6 | | 3 | | 2.01 (0.50–8.01)^†^
| | | | Stroke | 9 | | 5 | | 1.81 (0.61–5.38)^†^
| | | | Endometrial cancer | | | | | NA
| | | | All cause death | 6 | | 9 | | 0.67 (0.24–1.88)^†^
Raloxifene (60 or 120 mg per day)
Multiple Outcomes of Raloxifene Evaluation (Cummings et al, 1999)^64^ | Postmenopausal women with osteoporosis. | 5129 raloxifene | 40 | Thromboembolic event | 49 | | 8 | | 3.1 (1.5–6.2)
| Median age 66.9 years; 10% on estrogen. | 2576 placebo | | Pulmonary embolism | 17 | | 3 | | 2.85 (0.83–9.7)^†^
| | | | Deep vein thrombosis | 38 | | 5 | | 3.82 (1.50–9.69)^†^
| | | | Stroke | | | | | NA
| | | | Endometrial cancer | 6 | | 4 | | 0.8 (0.2–2.7)
| | | | All cause death | | | | | NA

NA, not available.

* Per 1,000 woman-years.

† Calculated.

Figure 5. Relative Risk (RR) of Thromboembolic Events in Chemoprevention Trials

Figure 6. Relative Risk (RR) of Stroke in Chemoprevention Trials

Figure 7. Relative Risk (RR) of Endometrial Cancer in Chemoprevention Trials

Figure 8. Relative Risk (RR) of All Cause Death in Chemoprevention Trials

Significantly more women in the tamoxifen group of the BCPT P-1 study developed cataracts during the course of the study than women in the placebo group (RR 1.14; 1.01–1.29).^60^ This finding was not reported in the other trials. Tamoxifen trials reported significantly increased hot flashes,^59^–^61^ vaginal discharge, bleeding, and other gynecologic problems,^59^–^61^ brittle nails,^59^ and mood changes.^61^

A report on quality of life indicators from the BCPT P-1 study indicated increased vasomotor symptoms (hot flashes, cold sweats, night sweats), increased gynecologic symptoms (vaginal discharge, itching), and relatively small (<4%) but consistent differences in three domains of sexual functioning (decreased sexual interest, arousal, and orgasm) in the tamoxifen group.^212^ There were no differences between groups on measures of mental health including depression.^212^

Adverse effects reported in the MORE trial by at least 2% of each raloxifene group and more frequently than the placebo group included flu syndrome (13%), hot flashes (10% to 12%), leg cramps (7%), endometrial cavity fluid (8% to 9%), and peripheral edema (5% to 7%).^64,^ ^192^

### Prophylactic Surgery

#### Mastectomy

Little information exists about the complications of prophylactic mastectomy in healthy high-risk women, and data from breast cancer patients may not be generalizable. In a series of 112 high-risk women (79 mutation carriers) who had prophylactic mastectomies with immediate reconstruction, 21% had complications including hematoma, infection, contracture, or implant rupture.^213^ Use of autologous tissue may eliminate the need for silicone implants but may result in higher complication rates.^71^

#### Oophorectomy

Surgical complications attributable to prophylactic oophorectomy are not well described and may vary with the type of surgical technique (laparotomy versus laparoscopy).^214^ A study of operative techniques used for 180,000 hysterectomies in 180 hospitals in the U.S. indicated an incidence of less than 3% for complications such as infection, bleeding, and urinary tract and bowel injury.^215^ Only one study of prophylactic oophorectomy in BRCA mutation carriers reported surgical complications.^74^ In this study, 4 of 80 women experienced complications including wound infection, perforation of the bladder, distal obstruction of the small bowel attributed to adhesions, and perforation of the uterus.^74^

Premenopausal high-risk women are not only the most likely to benefit from prophylactic oophorectomy, but are also the most likely to experience side effects from the surgery, including loss of fertility. Induction of premature menopause with associated symptoms of hot flashes, vaginal dryness, sexual dysfunction, sleep disturbances, and other symptoms, as well as increased osteoporosis, need to be considered. Use of postmenopausal hormone therapy can relieve symptoms^216^ and protect against osteoporotic fractures,^217^ but may also increase risk for breast cancer,^218^ although use of estrogen without progestin may prove less harmful.^219^ Lack of data for BRCA mutation carriers specifically complicates these management decisions.^220,^ ^221^

#### Psychosocial Impact

Few descriptive studies of the psychosocial impact of prophylactic mastectomy or oophorectomy on high-risk patients have been published. Patient surveys indicate that although 57% of women at high risk for breast cancer consider prophylactic mastectomy an option,^222^ only 16% to 20% rate it as a favorable option,^223,^ ^224^ and only 9% to 17% of women actually proceed with the surgery.^222,^ ^224,^ ^225^

The largest study of patient impact evaluated patients' long-term satisfaction and psychological and social function following prophylactic mastectomy at the Mayo Clinic after mean follow-up of 14.5 years.^226^ Overall, 70% of women were satisfied with the procedure, 11% neutral, and 19% dissatisfied. A majority (74%) reported diminished levels of emotional concern about developing breast cancer after mastectomy. Substantial minorities of women reported dissatisfaction with body appearance (36%), feelings of femininity (25%), sexual relationships (23%), self-esteem (18%), level of stress (14%), and emotional stability (9%).^226^

A study using a prophylactic mastectomy registry consisting of a volunteer population with mean follow-up of nearly 15 years postmastectomy indicated that 5% expressed regrets about the procedure.^227^ The only significant factor distinguishing those with regrets from those without was that the discussion concerning prophylactic mastectomy was initiated by their physicians rather than by themselves (p<0.05).^227^ In this study, 90% of those who were unhappy with their surgery had no preoperative psychological counseling.^227^

A prospective study of psychological morbidity of patients choosing to undergo prophylactic mastectomy and those of similar risk declining mastectomy administered six questionnaires preoperatively and again 6 and 18 months postoperatively.^228^ Although both groups had similar levels of distress at baseline, distress decreased significantly over time for women undergoing surgery (58% preoperative; 41% at 6 months, p=0.04; 29% at 18 months, p<0.001), but not for women declining surgery (57% preoperative; 43% at 6 months, p=0.08; 41% at 18 months, p=0.11).^228^

In another small study of women at increased risk for breast cancer because of family history, women selecting surgery reported more breast cancer worry, had higher estimated risk, and more previous breast biopsies than those declining.^222^ Women completing surgery were satisfied with their decision, although satisfaction with reconstruction was mixed.^222^

A prospective study on the impact of oophorectomy on women without cancer but with a strong family history of breast and/or ovarian cancer showed that prophylactic oophorectomy reduced anxiety about ovarian cancer (p=0.029).^229^ Most (86.4%) of the 22 women who had the procedure reported a high degree of satisfaction with their decision at 3-year follow-up.^229^ Other studies of the effects of oophorectomy in the general population focus on sexuality, mood, and menopausal symptoms and are inconclusive.^230^–^232^ A small retrospective study of high-risk women compared psychosocial outcomes of women undergoing prophylactic oophorectomy with those undergoing intensive screening.^233^ Women undergoing oophorectomy had significantly poorer scores on the role-emotional and social functioning scales of the Short Form-36 Health Status Questionnaire, and reported more menopausal symptoms on the General Health Questionnaire. There were no significant differences between groups for cancer worry or sexual functioning.^233^

## Outcomes Table

A summary of the evidence, including the level and quality of evidence, for each key question addressed in the evidence synthesis is provided in Table 12. No trials of screening for BRCA mutations in the general population that provide direct measures of benefits and adverse effects are available. In the absence of such trials, synthesis of data from indirect evidence can provide estimates. An outcomes table was developed to determine the magnitude of potential benefits and adverse effects of screening for BRCA mutations in the general population stratified by average, moderate, and high risk for mutations according to family history as previously defined. A summary of the assumptions and outcomes for the general population is provided in Table 13, and additional outcomes tables with sensitivity analyses are in Appendix S. Each assumption is associated with uncertainties and ranges of potential estimates that may not be fully considered in calculating the outcomes.

Table 12 Summary of Evidence Table

Key question | Level of evidence | Conclusions | USPSTF quality | Generalizability
1. Does risk assessment and BRCA mutation testing lead to a reduction in the incidence of breast and ovarian cancer and cause-specific and/or all cause mortality? | | No studies
2. What are the ethical, legal, and social implications of genetic screening for breast and ovarian cancer susceptibility? | Observational studies and RCTs | Studies summarized under related key questions (3b, 4, 6)
3a. How well does risk assessment for cancer susceptibility by a clinician in a primary care setting select candidates for BRCA mutation testing? | Descriptions of assessment tools and referral guidelines, only a few validation studies in populations of women at high risk | Assessment tools that estimate risk of BRCA mutation are available to clinicians, but most have not been evaluated in primary care settings. Several referral guidelines have been developed for primary care use but there is no consensus or gold standard for use. Studies of effectiveness in primary care settings are lacking. | Could not rate this design by USPSTF criteria | Tools developed from populations of women with breast and ovarian cancer
3b. What are the benefits of genetic counseling prior to testing? | RCTs with risk perception and distress outcomes | Genetic counseling may increase accuracy of risk perception and decrease breast cancer worry, anxiety, and depression. | Fair-good | Women in studies had all levels of risk, but were from highly selected specialty populations, white, and had high socioeconomic status.
3c. Among women with family histories predicting either an average, moderate, or high risk for a deleterious mutation, how well does BRCA mutation testing predict risk of breast and ovarian cancer? | Family linkage and population studies of prevalence and penetrance | Estimates of risk based on prevalence and penetrance can be stratified by family history risk groups that are applicable to screening. However, studies are heterogeneous and estimates based on them may not be reliable. | Could not rate this design by USPSTF criteria | Estimates most often from highly selected populations of women with breast and ovarian cancer
4. What are the adverse effects of risk assessment, counseling, and testing? | Observational studies and RCTs with distress outcomes | More studies showed decreased rather than increased distress after risk assessment, genetic counseling, and testing. | Fair-good | Women in studies had all levels of risk, but were from highly selected specialty populations, white, and had high socioeconomic status.
5. How well do interventions reduce the incidence and mortality of breast and ovarian cancer in women identified as high-risk by history, positive genetic test results, or both? | | Relative risk or hazard ratio (95% CI)
| | Breast cancer cases
Tamoxifen (20 mg per day) | Meta-analysis of 4 RCTs | 0.68 (0.51–0.91) | Fair-good | 3 trials included women with increased risk of breast cancer
Raloxifene (60 or 120 mg per day) | 1 RCT | 0.35 (0.21–0.58) | Good | Postmenopausal women with osteoporosis
Prophylactic mastectomy | Prosp cohort | 0 (0–0.36); p<0.003 | Fair | Women with BRCA mutations
Prophylactic oophorectomy | Retro cohort | 0.47 (0.29–0.77) | Fair | Women with BRCA mutations
| Prosp cohort | 0.32 (0.08–1.20) | Fair | Women with BRCA mutations
| | Ovarian cancer cases
| Retro cohort | 0.04 (0.01–0.16) | Fair | Women with BRCA mutations
| Prosp cohort | 0.15 (0.02–1.31) | Fair | Women with BRCA mutations
6. What are the adverse effects of interventions?
Thromboembolism: tamoxifen and raloxifene | Meta-analysis of 5 RCTs | 2.21 (1.63–2.98) | Fair-good
Stroke: tamoxifen | Meta-analysis of 3 RCTs | 1.50 (1.00–2.24)
Endometrial cancer: tamoxifen | Meta-analysis of 3 RCTs | 2.42 (1.46–4.03)
All cause death: tamoxifen | Meta-analysis of 4 RCTs | 1.14 (0.64–2.05)
Surgical complications | Observational | 21% Mastectomy | Fair | Women with high family risk or BRCA mutations
| | 5% Ooophorectomy
Psychological harms | Descriptive | Patient satisfaction with surgery is mixed; cancer distress improves, but self-esteem, body image, and other outcomes are adversely affected in some women. | Could not rate this design by USPSTF criteria | Few studies, small study samples

Prosp, prospective; RCT, randomized controlled trials; Retro, retrospective; USPSTF, U.S. Preventive Services Task Force.

Table 13 Outcomes Table Summary

Assumptions | Risk level
| Average | Moderate | High
Number of women screened | 100,000 | 100,000 | 100,000
Prevalence of clinically significant BRCAmutations (%)
BRCA1 | 0.06 | 0.75 | 4.34
BRCA2 | 0.06 | 0.75 | 4.34
Penetrance of mutation to age 40/50 (%)
Breast cancer (to age 40 years)
BRCA1 | 14.98 (10.04–21.77) | 13.19 (5.29–29.23) | 11.29 (7.75–16.16)
BRCA2 | 13.93 (9.79–21.36) | 8.42 (5.45–12.79) | No data
Ovarian cancer (to age 50 years)
BRCA1 | 33.09 (25.29–41.94) | No data | No data
BRCA2 | 9.34 (4.15–16.69) | No data | No data
Penetrance of mutation to age 75 (%)
Breast cancer
BRCA1 | 68.58 (47.73–83.91) | 49.88 (27.52–72.29) | 60.53 (52.34–68.17)
BRCA2 | No data | No data | 53.00 (42.20–63.52)
Ovarian cancer
BRCA1 | 29.21 (20.25–40.13) | 55.05 (48.41–61.51) | 26.14 (21.98–30.76)
BRCA2 | 34.22 (22.93–47.64) | 27.03 (17.30–39.60) | 6.43 (3.41–11.82)
Risk reduction of SERMs to prevent all types of breast cancer, trials with mutation status unknown (RR=0.62; 0.46–0.83) | 0.38 (0.17–0.54) | 0.38 (0.17–0.54) | 0.38 (0.17–0.54)
Risk of thromboembolic events from SERMs (% per year) | 0.096 (0.036–0.156) | 0.096 (0.036–0.156) | 0.096 (0.036–0.156)
Risk of endometrial cancer from SERMs (% per year) | 0.036 (0.00177–0.0709) | 0.036 (0.00177–0.0709) | 0.036 (0.00177–0.0709)
Proportion of candidates choosing SERMs (%) (not known) | Uniform (5, 50) | Uniform (5, 50) | Uniform (5, 50)
Risk reduction of mastectomy to prevent breast cancer if BRCA mutation (RR=0; 0–0.36) | 0.91(0.64–1.00) | 0.91(0.64–1.00) | 0.91(0.64–1.00)
Risk of complications from mastectomy and reconstruction (% overall) (based on one study; range not known) | 21 | 21 | 21
Proportion of candidates choosing mastectomy (%) (not known) | Uniform (5, 20) | Uniform (5, 20) | Uniform (5, 20)
Risk reduction of oophorectomy to prevent breast cancer if BRCA mutation (RR=0.32; 0.08–1.20) | 0.68 (0.01–0.92) | 0.68 (0.01–0.92) | 0.68 (0.01–0.92)
Risk of complications from oophorectomy (% overall) (based on one study; range not known) | 5 | 5 | 5
Proportion of candidates choosing oophorectomy (%) (not known) | Uniform (25, 75) | Uniform (25, 75) | Uniform (25, 75)
Risk reduction of oophorectomy to prevent ovarian cancer in BRCAmutation (RR-0.15; 0.02–2.31) | 0.85 (0.01–0.99) | 0.85 (0.01–0.99) | 0.85 (0.01–0.99)
Risk of complications from oophorectomy (% overall) (based on one study; range not known) | 5 | 5 | 5
Proportion of candidates choosing oophorectomy (%) (not known) | Uniform (25, 75) | Uniform (25, 75) | Uniform (25, 75)
Outcomes-benefits to age 40 and 50
Number of breast cancer cases expected among candidates if not undergoing treatment | 17.5 (13.0–23.3) | 164 (98–287) | 1315 (845–2047)
Number of breast cancer cases prevented among candidates taking SERMs (using overall risk reduction of 0.38) | 1.7 (0.33–4.1) | 15.5 (2.9–44.6) | 125 (24–335)
NNS to prevent 1 case of breast cancer using SERMs | 59826 (24285–301547) | 6438 (2243–34388) | 801(300–4176)
NNT with SERMs to prevent 1 case of breast cancer | 18.3 (11.3–43.2) | 24.6 (12.3–63.2) | 17.7 (9.8–43.6)
Number of breast cancer cases prevented among candidates undergoing mastectomy | 1.9 (0.77–3.7) | 18.0 (6.5–41.2) | 145 (54–304)
NNS to prevent 1 case of breast cancer using mastectomy | 51469 (27396–129503) | 5548 (2426–15433) | 691(329–1845)
NNT with mastectomy to prevent 1 case of breast cancer | 7.5 (5.4–11.6) | 10.1 (5.6–18.2) | 7.3 (4.5–12.3)
Number of breast cancer cases prevented among candidates if undergoing oophorectomy | 5.2 (0.0084–11.3) | 49 (0.78–125) | 393 (6–929)
NNS to prevent 1 case of breast cancer using oophorectomy | 19067 (8820–1189273) | 2045 (802–128155) | 255 (108–16057)
NNT with oophorectomy to prevent 1 case of breast cancer | 10.4 (6.5–692) | 14.3 (7.0–928) | 10.2 (5.5–670)
Number of ovarian cancer cases expected among candidates if not undergoing treatment | 25.7 (19.7–33.5) | No data | No data
Number of ovarian cancer cases prevented among candidates undergoing oophorectomy | 9.5 (0.12–18.8) | No data | No data
NNS to prevent 1 case of ovarian cancer using oophorectomy | 10489 (5305–864679) | No data | No data
NNT with oophorectomy to prevent 1 case of ovarian cancer | 5.7 (4.0–481) | No data | No data
Outcomes-benefits to age 75
Number of breast cancer cases expected among candidates if not undergoing treatment | 82 (65–96) | 748 (508–989) | 4925 (4341–5493)
Number of breast cancer cases prevented among candidates taking SERMs (using overall risk reduction of 0.38) | 7.8 (1.6–18.4) | 71 (14–177) | 474 (96–1100)
NNS to prevent 1 case of breast cancer using SERMs | 12862 (5425–64048) | 1419 (567–7237) | 211 (91–1043)
NNT with SERMs to prevent 1 case of breast cancer | 3.9 (2.6–9.1) | 5.4 (3.3–13.1) | 4.7 (3.2–10.7)
Number of breast cancer cases prevented among candidates undergoing mastectomy | 9.1 (3.7–16.0) | 82 (32–157) | 550 (230–943)
NNS to prevent 1 case of breast cancer using mastectomy | 11049 (6243–27037) | 1222 (639–3142) | 182 (107–435)
NNT with mastectomy to prevent 1 case of breast cancer | 1.6 (1.3–2.4) | 2.2 (1.6–3.6) | 1.9 (1.6–2.8)
Number of breast cancer cases prevented among candidates if undergoing oophorectomy | 24.4 (0.39–50.4) | 222 (3.5–486) | 1483 (24–2990)
NNS to prevent 1 case of breast cancer using oophorectomy | 4100 (1985–255926) | 452 (206–28242) | 68 (34–4204)
NNT with oophorectomy to prevent 1 case of breast cancer | 2.2 (1.5–148) | 3.1 (1.9–203) | 2.6 (1.9–177.0)
Number of ovarian cancer cases expected among candidates if not undergoing treatment | 38 (29–48) | 616 (527–721) | 1422 (1186–1718)
Number of ovarian cancer cases prevented among candidates undergoing oophorectomy | 14.1 (0.17–27.7) | 230 (2.8–431) | 530 (6.4–1006)
NNS to prevent 1 case of ovarian cancer using oophorectomy | 7072 (3610–584750) | 436 (232–35652) | 189 (100–15565)
NNT with oophorectomy to prevent 1 case of ovarian cancer | 3.9 (2.7–323) | 2.9 (2.3–248) | 7.4 (5.5–624.3)
Outcomes-adverse effects
Number of women taking SERMs | 33 (7.3–59) | 412 (92–733) | 2386 (532–4242)
Number of cases of thrombotic events due to SERMs | 0.032 (0.005–0.073) | 0.40 (0.068–0.91) | 2.29 (0.40–5.28)
NNT with SERMs to cause one thrombotic event | 1042 (641–2719) | 1042 (641–2719) | 1042 (641–2719)
Number of cases of endometrial cancer due to SERMs | 0.012 (0.00039–0.032) | 0.15 (0.005–0.40) | 0.87 (0.029–2.32)
NNT with SERMs to cause one case of endometrial cancer | 2686 (1228–15726) | 2686 (1228–15726) | 2686 (1228–15726)
Number of women undergoing mastectomy | 15.0 (6.4–23.6) | 188 (80.6–294) | 1085 (467–1703)
Number of women with complications from mastectomy | 3.2 (1.4–4.9) | 39.4 (16.9–61.8) | 228 (98–358)
NNT with mastectomy to cause one complication | 5 | 5 | 5
Number of women undergoing oophorectomy | 60 (32–89) | 750 (394–1106) | 4342 (2279–6401)
Number of women with complications from oophorectomy | 3.0 (1.6–4.4) | 37.5 (19.7–55.3) | 217 (114–320)
NNT oophorectomy to cause one complication | 20 | 20 | 20

NNS, number needed to screen; NNT, number needed to treat; SERMs, selective estrogen receptor modulators.

Estimates of the prevalence of BRCA1 and BRCA2 mutations were based on best estimates from published studies and results of the meta-analysis when multiple studies were available (Table 5). For the average- and moderate-risk groups, ranges of prevalence rates were used to represent a range of risk. Estimates of the penetrance of breast and ovarian cancer in those with clinically significant mutations were based on results of the meta-analysis of published studies (Tables 6 and 7). An estimate of risk reduction by using chemoprophylaxis with SERMs was obtained from the meta-analysis of chemoprevention trials (Figure 3). Estimates of risk reduction from preventive mastectomy or oophorectomy surgeries were obtained from studies determined to be of the highest quality.^70,^ ^74^ Risks of complications from drugs or surgeries were determined from the same studies as the treatment effects. Estimates of the proportion of candidates choosing SERMs, mastectomy, or oophorectomy were based on surveys of patient preferences and compliance during clinical trials and were discussed with experts.^222,^ ^224,^ ^225^ Calculations assumed that women are cancer free at age 20, and outcomes were calculated to age 40/50 and age 75 years.

Results for the general population are summarized in Table 13 and Figures 9 and 10. These estimates assume prevalence rates of mutations of 0.12% for average-risk, 1.5% for moderate-risk, and 8.7% for high-risk women. This combination of prevalence rates reflects an overall population mutation rate of 1 in 397. The NNS to prevent one case of breast cancer in a hypothetical cohort of 100,000 women is dependent on which prevention therapy is chosen. For women with average risk, the NNS to prevent one case of breast cancer by the age of 75 years by using a SERM is 12,862 (5,425–64,048), for mastectomy 11,049 (6,243–27,037), and for oophorectomy 4,100 (1,985–255,926). Approximately 7,072 (3,610–584,750) women with average risk need to be screened to prevent one case of ovarian cancer by undergoing oophorectomy. The NNS for all treatment options, and for both breast and ovarian cancer outcomes, decreases as risk for mutations increases. For women with high risk, the NNS to prevent one case of breast cancer by using a SERM is 211 (91–1,043), mastectomy 182 (107–435), and oophorectomy 68 (34–4,204); and the NNS to prevent one case of ovarian cancer by undergoing oophorectomy is 189 (100–15,565). Under the assumptions of the outcomes table, if 100,000 women in the general population underwent screening for BRCA mutations, 16 cases of breast cancer would be prevented using mastectomy and 31 cases of ovarian cancer would be prevented using oophorectomy (Figure 11).

Figure 9. Number Needed to Screen for BRCA Mutations by Risk Groups to Prevent One Case of Breast or Ovarian Cancer to Age 75

Figure 10. Number Needed to Screen for BRCA Mutations by Risk Groups to Prevent One Case of Breast Cancer to Age 40 or Ovarian Cancer to Age 50

Figure 11. Yield of Testing in A Hypothetical Population Based on Assumptions in Table 13

Adverse effects are also described in Table 13. The number needed to treat with SERMs to cause a thromboembolic event each year is 1,042 (641–2,719), and to cause a case of endometrial cancer each year is 2,686 (1,228–15,726) (tamoxifen only). Use of chemoprevention is a long-term prevention strategy, so these estimates require adjustment depending on the projected length of therapy. Only 5 women need to be treated with mastectomy in order to have one surgical complication, and 20 with oophorectomy. The numbers of women undergoing treatment and experiencing adverse effects increase with each successive risk group.

Sensitivity analyses indicate that preventing breast and ovarian cancer cases that occur by age 40 to 50 require higher NNS than those that occur by age 75, although women in the high-risk group have a much lower NNS than those in lesser risk groups (Appendix S). In general, the NNS for Ashkenazi Jewish women is lower than in the general population (Appendix S). Also, the prevalence ratios of BRCA1 and BRCA2 do not substantially influence the NNS, and if lower prevalence assumptions are used, the NNS increases.