# Methods

## Literature Search Strategy

Relevant papers were identified from multiple searches of MEDLINE® (1966 to October 1, 2004) and the Cochrane Library databases. Search strategies are described in Appendix A. Additional papers were obtained by reviewing reference lists of pertinent studies, reviews, editorials, and websites, and by consulting experts.

## Inclusion/Exclusion Criteria

Investigators reviewed all abstracts identified by the searches and determined eligibility by applying inclusion and exclusion criteria specific to key questions (Appendix B). Full-text papers of included abstracts were then reviewed for relevance. Eligible studies had English-language abstracts, were applicable to U.S. clinical practice, and provided primary data relevant to key questions. Studies about patients with current or past breast or ovarian cancer were excluded unless they were designed to address screening issues in women without cancer (e.g., retrospective or case-control studies).

## Data Extraction and Synthesis

All eligible studies were reviewed and a “best evidence” approach was applied.^84^ Data were extracted from each study, entered into evidence tables, and summarized by descriptive and statistical methods as appropriate. Two reviewers independently rated the quality of studies using criteria specific to different study designs developed by the USPSTF (Appendix C). When reviewers disagreed, a final rating was determined by reevaluations by the two initial reviewers and a third reviewer if needed.

## Statistical Analysis

To estimate risks for breast and ovarian cancer due to clinically significant BRCA mutations, the screening population was stratified into groups at average, moderate, and high risk for carrying a mutation based on history of breast or ovarian cancer in first- and second-degree relatives. This approach allows use of published data that describe risks in similar terms. The following definitions were used:

- Average risk: No first-degree relatives and no more than one second-degree relative on each side of the family with breast or ovarian cancer.
- Moderate risk: One first-degree relative or two second-degree relatives on the same side of the family with breast or ovarian cancer.
- High risk: At least two first-degree relatives with breast or ovarian cancer.

Based on pooled data from over 100,000 women without breast cancer from 52 epidemiologic studies of familial breast cancer, approximately 93% of the screening population would be expected to be average risk, 7% moderate risk, and 0.4% high risk by these definitions.^85^

Ashkenazi Jewish women have higher risks for clinically significant BRCA mutations even if they have no affected first-degree relatives. In certain areas of the U.S., this group comprises an important proportion of women in primary care practices. For screening purposes, they were categorized in the following groups:

- Moderate risk: No first-degree relatives and no more than one second-degree relative on each side of the family with breast or ovarian cancer.
- High risk: At least one first-degree relative or two second-degree relatives on the same side of the family with breast or ovarian cancer.

Based on data from nearly 5,000 Jewish men and women living in the Washington, D.C., area of the U.S., approximately 79% of the screening population would be expected to be moderate risk, and 21% high risk by these definitions, although these estimates may vary regionally.^86^

Risks for developing breast and ovarian cancer in mutation carriers have been primarily calculated from families of women with existing breast and ovarian cancer. Determinations of risk in mutation carriers without these conditions are limited. To determine benefits and adverse effects of genetic testing in average-, moderate-, and high-risk groups, estimates of mutation prevalence as well as the probability of developing cancer given the presence of the mutation (penetrance) were determined for each risk group. Penetrance was calculated from data about the prevalence of BRCA mutations in women with and without breast and ovarian cancer, the probability of breast and ovarian cancer in the U.S. population estimated from SEER data^248^ by using DevCan software,^87^ and relative risks of breast and ovarian cancer in moderate- and high-risk groups.

For the meta-analysis of mutation prevalence for each risk group, the approach by DerSimonian and Laird was adopted,^88^ where the logit of the prevalence and the corresponding standard errors were calculated for each study and used in the meta-analysis. The overall estimate of prevalence and its corresponding variance were then used to estimate penetrance. The meta-analysis of penetrance was based on Bayes' theorem and stratified by cancer type (breast or ovarian), risk group (average, moderate, and high), and age whenever data were available. Additional details of this method are provided in Appendix D.

A meta-analysis of chemoprevention trials was also performed to provide more precise estimates of effectiveness and adverse effects. All chemoprevention trials reported relative risk (RR) estimates, and the logarithm of the RR (logRR) and the corresponding standard errors were calculated for each trial and used in the meta-analysis. The overall estimates of RR were obtained by using a random effects model.^88^

An outcomes table was developed to determine the magnitude of potential benefits and adverse effects of testing for BRCA mutations in the general population stratified by average, moderate, and high risk for a mutation based on family history as defined above. The number needed to treat (NNT) and number needed to screen (NNS) as well as other outcome variables were calculated from best estimates of assumption variables from published studies and results of analyses when available. Variation associated with these estimates was incorporated by using Monte Carlo simulations. The sampling distributions for estimates were either the underlying distribution on which calculation of the 95% confidence interval (CI) was based when available, or one that best approximated the point estimate and confidence interval. For example, if the assumption variable was penetrance, the logit of penetrance was approximately normally distributed and sampled, then transformed back to its original scale. For relative risk, the log of relative risk was approximately normally distributed. Risk reduction was calculated from the sampled log of relative risk. The point estimate and 95% confidence interval of NNT, NNS, and other outcome variables were based on 1,000,000 simulations.

Since there are no direct estimates of BRCA mutation prevalence for average- and moderate-risk groups, sensitivity analyses were conducted by assuming a range of prevalence values. Prevalence values were chosen such that when they were summed across the three risk groups, the total fell within the range for the general population (1 in 300 to 500).^30,^ ^89^ Calculations assumed that women are cancer free at age 20, and outcomes were calculated to age 40 years for breast cancer, age 50 years for ovarian cancer, and age 75 years for both because results at these ages were most often reported by studies. It was assumed that one-half of the mutations would be in BRCA1 and one-half in BRCA2, and sensitivity analyses were also performed to determine whether this ratio (40/60, 50/50, 60/40) affects outcomes.

## Size of Literature Reviewed

Investigators reviewed 2,211 abstracts identified by the searches (Appendix E), and excluded 1,380 articles from further review because they focused on excluded populations or did not address key questions. From the searches, 835 full-text articles were reviewed. An additional 279 non-duplicate articles identified from reference lists and experts were also reviewed.

Appendix E. Search and Selection of Literature