# Appendix J. Evidence Table of Studies of Prevalence of Mutation Among Breast or Ovarian Cancer Cases

Author, year | Population | Cancer | AJ | Risk for mutation* | N tested | N BRCA1 positive | N BRCA2 positive | N BRCA1 or BRCA2 positive | BRCA1 mutation frequency | BRCA2 mutation frequency | BRCA1 or BRCA2 mutation frequency
Abeliovich et al, 1997^152^ | Hospital-based (Israel) AJ women | B | Y | FH-NS | 185 | 19 | 10 | 29 | 10.3% | 5.4% | 15.7%
Abeliovich et al, 1997 | Hospital-based (Israel) AJ women | B | Y | Hgh | 64 | 16 | 5 | 21 | 25.0% | 7.8% | 32.8%
Abeliovich et al, 1997 | Hospital-based (Israel) AJ women | B | Y | Mod | 99 | 3 | 7 | 10 | 3.0% | 7.1% | 10.1%
Abeliovich et al, 1997 | Hospital-based (Israel) AJ, age: < 30 yrs | B | Y | FH-NS | 6 | 1 | 2 | 3 | 16.7% | 33.3% | 50.0%
Abeliovich et al, 1997 | Hospital-based (Israel) AJ, age: 30–40 yrs | B | Y | FH-NS | 38 | 10 | 1 | 11 | 26.3% | 2.6% | 28.9%
Abeliovich et al, 1997 | Hospital-based (Israel) AJ, age: 40–50 yrs | B | Y | FH-NS | 65 | 3 | 3 | 6 | 4.6% | 4.6% | 9.2%
Abeliovich et al, 1997 | Hospital-based (Israel) AJ, age: 50–65 yrs | B | Y | FH-NS | 59 | 4 | 4 | 8 | 6.8% | 6.8% | 13.6%
Abeliovich et al, 1997 | Hospital-based (Israel) AJ, age: > 65 yrs | B | Y | FH-NS | 17 | 1 | 0 | 1 | 5.9% | 0.0% | 5.9%
Abeliovich et al, 1997 | Hospital-based (Israel) AJ women | O | Y | FH-NS | 21 | 7 | 6 | 13 | 33.3% | 28.6% | 61.9%
Abeliovich et al, 1997 | Hospital-based (Israel) AJ, age: < 30 yrs | O | Y | FH-NS | 0 | 0 | 0 | 0
Abeliovich et al, 1997 | Hospital-based (Israel) AJ, age: 30–40 yrs | O | Y | FH-NS | 1 | 1 | 0 | 1 | 100.0% | 0.0% | 100.0%
Abeliovich et al, 1997 | Hospital-based (Israel) AJ, age: 40–50 yrs | O | Y | FH-NS | 5 | 1 | 1 | 2 | 20.0% | 20.0% | 40.0%
Abeliovich et al, 1997 | Hospital-based (Israel) AJ, age: 50–65 yrs | O | Y | FH-NS | 12 | 4 | 4 | 8 | 33.3% | 33.3% | 66.7%
Abeliovich et al, 1997 | Hospital-based (Israel) AJ, age: > 65 yrs | O | Y | FH-NS | 3 | 1 | 1 | 2 | 33.3% | 33.3% | 66.7%
Anglian Breast Cancer Study Group, 2000^27^ | Population-based series (UK), diagnosed < 55 yrs | B | N | FH-NS | 1,435 | 8 | 16 | 24 | 0.6% | 1.1% | 1.7%
Anglian Breast Cancer Study Group, 2000 | Population-based series (UK), diagnosed < 55 yrs | B | N | Avg | 1,124 | | | 11 | | | 1.0%
Anglian Breast Cancer Study Group, 2000 | Population-based series (UK), diagnosed < 55 yrs | B | N | Mod | 197 | | | 7 | | | 3.6%
Anglian Breast Cancer Study Group, 2000 | Population-based series (UK), diagnosed < 55 yrs | B | N | Hgh | 27 | | | 4 | | | 14.8%
Anglian Breast Cancer Study Group, 2000 | Population-based series (UK), diagnosed < 55 yrs | B | N | FH-NS | 57 | 2 | 4 | 6 | 3.5% | 7.0% | 10.5%
| Age: < 35
Anglian Breast Cancer Study Group, 2000 | Population-based series (UK), diagnosed < 55 yrs | B | N | FH-NS | 341 | 3 | 4 | 7 | 0.9% | 1.2% | 2.1%
| Age: 35–44
Anglian Breast Cancer Study Group, 2000 | Population-based series (UK), diagnosed < 55 yrs | B | N | FH-NS | 917 | 3 | 8 | 11 | 0.3% | 0.9% | 1.2%
| Age: 45–54
Anton-Culver et al, 2000^144^ | Population-based (US) | B | N | FH-NS | 671 | 11 | | | 1.6%
Anton-Culver et al, 2000 | Population-based (US) | B | N | Avg | 432 | 5 | | | 1.2%
Anton-Culver et al, 2000 | Population-based (US) | B | N | Mod | 120 | 4 | | | 3.3%
Anton-Culver et al, 2000 | Population-based (US) | B | N | Hgh | 29 | 2 | | | 6.9%
Anton-Culver et al, 2000 | AJ (US) Breast cancer | B | Y | FH-NS | 30 | 2 | | | 6.7%
Anton-Culver et al, 2000 | Population-based (US) | O | N | FH-NS | 99 | 4 | | | 4.0%
Anton-Culver et al, 2000 | Population-based (US) | O | N | Avg | 81 | 0 | | | 0.0%
Anton-Culver et al, 2000 | Population-based (US) | O | N | Mod | 17 | 3 | | | 17.6%
Anton-Culver et al, 2000 | Population-based (US) | O | N | Hgh | 1 | 1 | | | 100.0%
Antoniou et al, 2002^28^ | Families with ≥ 2 breast cancers, one of which diagnosed < 50 yrs (UK) | B | N | HGH | 156 | 21 | 18 | 39 | 13.5% | 11.5% | 25.0%
Boyd et al, 2000^154^ | Consecutive series from cancer center (US) | O | Y | FH-NS | 189 | 67 | 21 | 88 | 35.4% | 11.1% | 46.6%
| Jewish
Boyd et al, 2000 | Consecutive series from cancer center (US) | O | Y | FH-NS | 7 | 4 | 0 | 4 | 57.1% | 0.0% | 57.1%
| Jewish, age: < 40
Boyd et al, 2000 | Consecutive series from cancer center (US) | O | Y | FH-NS | 38 | 21 | 4 | 25 | 55.3% | 10.5% | 65.8%
| Jewish, age: 40–49
Boyd et al, 2000 | Consecutive series from cancer center (US) | O | Y | FH-NS | 28 | 14 | 1 | 15 | 50.0% | 3.6% | 53.6%
| Jewish, age: 50–59
Boyd et al, 2000 | Consecutive series from cancer center (US) | O | Y | FH-NS | 68 | 19 | 11 | 30 | 27.9% | 16.2% | 44.1%
| Jewish, age: 60–69
Boyd et al, 2000 | Consecutive series from cancer center (US) | O | Y | FH-NS | 48 | 9 | 5 | 14 | 18.8% | 10.4% | 29.2%
| Jewish, age: > 70
Couch et al, 1997^31^ | Familial breast cancer clinic (US) | B | N | FH-NS | 94 | 12 | | | 12.8%
| Age: <40 yrs
Couch et al, 1997 | Familial breast cancer clinic (US) | B | N | Hgh | 169 | 27 | | | 16.0%
| Age: <35 yrs and FH
Couch et al, 1997 | Familial breast cancer clinic (US) | B | N | Hgh | 5 | 1 | | | 20.0%
| Age: <35 yrs and FH
Couch et al, 1997 | Familial breast cancer clinic (US) | B | N | Hgh | 27 | 7 | | | 25.9%
| Age: 35–39 yrs and FH
Couch et al, 1997 | Familial breast cancer clinic (US) | B | N | Hgh | 32 | 5 | | | 15.6%
| Age: 40–44 yrs and FH
Couch et al, 1997 | Familial breast cancer clinic (US) | B | N | Hgh | 24 | 5 | | | 20.8%
| Age: 45–49 yrs and FH
Couch et al, 1997 | Familial breast cancer clinic (US) | B | N | Hgh | 34 | 4 | | | 11.8%
| Age: 50–54 yrs and FH
Couch et al, 1997 | Familial breast cancer clinic (US) | B | N | Hgh | 24 | 1 | | | 4.2%
| Age: 55 – 59 yrs and FH
Couch et al, 1997 | Familial breast cancer clinic (US) | B | N | Hgh | 23 | 4 | | | 17.4%
| Age: >59 yrs and FH
Eccles et al, 1998^141^ | Clinically selected group (UK) | B | N | FH-NS | 155 | 10 | | | 6.5%
| Age: <40
Eccles et al, 1998 | Clinically selected group (UK) | B | N | Avg | 86 | 1 | | | 1.2%
| Age: <40 and No FH
Eccles et al, 1998 | Clinically selected group (UK) | B | N | Hgh | 40 | 9 | | | 22.5%
| Age: <40 and strong FH
Eccles et al, 1998 | Clinically selected group (UK) | B | N | Avg | 45 | 0 | | | 0.0%
| Age: >40 and bilateral cancer
Eccles et al, 1998 | Clinically selected group (UK) | B | N | Hgh | 30 | 8 | | | 26.7%
| Strong FH
Eccles et al, 1998 | Clinically selected group (UK) | O | N | Hgh | 16 | 7 | | | 43.8%
| Strong FH
FitzGerald et al, 1996^150^ | Breast cancer referral centers (US) | B | Y | FH-NS | 35 | 6 | | | 17.1%
| Jewish, age: 30–40
FitzGerald et al, 1996 | Breast cancer referral centers (US) | B | Y | FH-NS | 4 | 2 | | | 50.0%
| Jewish, age: ≤ 30
FitzGerald et al, 1996 | Breast-cancer referral centers (US) | B | Y | Hgh | 15 | 4 | | | 26.7%
| Jewish, age: ≤ 40
FitzGerald et al, 1996 | Breast-cancer referral centers (US) | B | Y | Mod | 24 | 4 | | | 16.7%
| Jewish, age: ≤ 40
FitzGerald et al, 1996 | Breast cancer referral centers (US) | B | N | FH-NS | 26 | 2 | | | 7.7%
| Non-AJ, age: <30
Fodor et al, 1998^125^ | Hospital-based (US) | B | Y | FH-NS | 268 | | | 18 | | | 6.7%
| AJ
Fodor et al, 1998 | Hospital-based (US) | B | Y | Mod | 212 | | | 14 | | | 6.6%
| AJ
Fodor et al, 1998 | Hospital-based (US) | B | Y | Hgh | 50 | | | 4 | | | 8.0%
| AJ
Frank et al, 1998^94^ | Referred population (US) | B | N | Mod | 200 | 47 | 23 | 70 | 23.5% | 11.5% | 35.0%
| Ethnicity nonselected
| Age: < 50
Frank et al, 1998 | Referred population (US) | B | N | Mod | 10 | 5 | 1 | 6 | 50.0% | 10.0% | 60.0%
| Ethnicity nonselected
| Age: 20 – 29
Frank et al, 1998 | Referred population (US) | B | N | Mod | 80 | 25 | 7 | 32 | 31.3% | 8.8% | 40.0%
| Ethnicity nonselected
| Age: 30–39
Frank et al, 1998 | Referred population (US) | B | N | Mod | 110 | 17 | 15 | 32 | 15.5% | 13.6% | 29.1%
| Ethnicity nonselected
| Age: 40–49
Frank et al, 1998 | Referred population (US) | O | N | Mod | 22 | 8 | 2 | 10 | 36.4% | 9.1% | 45.5%
| Ethnicity nonselected
Frank et al, 2002^33^ | Clinical consecutive samples (US) Non-AJ | B | N | Hgh | 2,549 | | | 489 | | | 19.2%
Frank et al, 2002 | Clinical consecutive samples (US) | B | N | Hgh | 661 | | | 61 | | | 9.2%
| Non-AJ, age: > 50
Frank et al, 2002 | Clinical consecutive samples (US) | B | N | Hgh | 1,026 | | | 161 | | | 15.7%
| Non-AJ, age: 40 – 49
Frank et al, 2002 | Clinical consecutive samples (US) | B | N | Hgh | 862 | | | 267 | | | 31.0%
| Non-AJ, age: < 40
Frank et al, 2002 | Clinical consecutive samples (US) | O | N | Hgh | 294 | | | 106 | | | 36.1%
| Non-AJ
Frank et al, 2002 | Clinical consecutive samples (US) | O | N | Hgh | 164 | | | 53 | | | 32.3%
| Non-AJ, age: > 50
Frank et al, 2002 | Clinical consecutive samples (US) | O | N | Hgh | 130 | | | 53 | | | 40.8%
| Non-AJ, age: < 50
Frank et al, 2002 | Clinical consecutive samples (US) | B | Y | Hgh | 904 | | | 195 | | | 21.6%
| AJ
Frank et al, 2002 | Clinical consecutive samples (US) | B | Y | Hgh | 326 | | | 36 | | | 11.0%
| AJ, age: > 50
Frank et al, 2002 | Clinical consecutive samples (US) | B | Y | Hgh | 390 | | | 88 | | | 22.6%
| AJ, age: 40–49
Frank et al, 2002 | Clinical consecutive samples (US) | B | Y | Hgh | 188 | | | 71 | | | 37.8%
| AJ, age: < 40
Frank et al, 2002 | Clinical consecutive samples (US) | O | Y | Hgh | 109 | | | 44 | | | 40.4%
| AJ
Frank et al, 2002 | Clinical consecutive samples (US) | O | Y | Hgh | 58 | | | 24 | | | 41.4%
| AJ, age: > 50
Frank et al, 2002 | Clinical consecutive samples (US) | O | Y | Hgh | 51 | | | 20 | | | 39.2%
| AJ, age: < 50
Gayther et al, 1999^149^ | Families with ovarian cancer (UK) | O | N | Hgh | 112 | 40 | 8 | 48 | 35.7% | 7.1% | 42.9%
| FH: ≥ 2 Ovarian cancer
Gershoni-Baruch et al, 2000^151^ | AJ woman with family early-onset breast cancer (Israel) | B | Y | FH-NS | 172 | 42 | 13 | 54 | 24.4% | 7.6% | 31.4%
| Age: <42
Gershoni-Baruch et al, 2000 | AJ woman with family early-onset breast cancer (Israel) | B | Y | Hgh | 79 | 36 | 10 | 45 | 45.6% | 12.7% | 57.0%
| Age: <42 yrs
Gershoni-Baruch et al, 2000 | AJ woman with family early-onset breast cancer (Israel) | B | Y | Mod | 93 | 6 | 3 | 9 | 6.5% | 3.2% | 9.7%
| Age: <42 yrs
Hartge et al, 1999^86^ | Population-based (US) | B | Y | FH-NS | 297 | | | 27 | | | 9.1%
| AJ
Hartge et al, 1999 | Population-based (US) | B | Y | Hgh | 95 | | | 13 | | | 13.7%
| AJ
Hartge et al, 1999 | Population-based (US) | B | Y | Mod | 204 | | | 14 | | | 6.9%
| AJ
Hartge et al, 1999 | Population-based (US) | B | Y | FH-NS | 34 | | | 9 | | | 26.5%
| AJ, age: < 40 yrs
Hartge et al, 1999 | Population-based (US) | B | Y | Hgh | 8 | | | 3 | | | 37.5%
| AJ, age: < 40 yrs
| FH
Hartge et al, 1999 | Population-based (US) | B | Y | Mod | 28 | | | 6 | | | 21.4%
| AJ, age: < 40 yrs
| Non-FH
Hartge et al, 1999 | Population-based (US) | B | Y | FH-NS | 109 | | | 11 | | | 10.1%
| AJ, age: 40–49 yrs
Hartge et al, 1999 | Population-based (US) | B | Y | Hgh | 36 | | | 6 | | | 16.7%
| AJ, age: 40–49 years
| FH
Hartge et al, 1999 | Population-based (US) | B | Y | Mod | 73 | | | 5 | | | 6.8%
| AJ, age: 40–49 years
| Non-FH
Hartge et al, 1999 | Population-based (US) | B | Y | FH-NS | 82 | | | 6 | | | 7.3%
| AJ, age: 50–59 yrs
Hartge et al, 1999 | Population-based (US) | B | Y | Hgh | 26 | | | 4 | | | 15.4%
| AJ, age: 50–59 years
| FH
Hartge et al, 1999 | Population-based (US) | B | Y | Mod | 56 | | | 2 | | | 3.6%
| AJ, age: 50–59 years
| Non-FH
Hartge et al, 1999 | Population-based (US) | B | Y | FH-NS | 72 | | | 1 | | | 1.4%
| AJ, age: > 60 yrs
Hartge et al, 1999 | Population-based (US) | B | Y | Hgh | 25 | | | 0 | | | 0.0%
| AJ, age: > 60 yrs
| FH
Hartge et al, 1999 | Population-based (US) | B | Y | Mod | 47 | | | 1 | | | 2.1%
| AJ, age: > 60 yrs
| Non-FH
Hopper et al, 1999^132^ | Population-based (Australia) | B | N | FH-NS | 388 | 9 | 9 | 18 | 2.3% | 2.3% | 4.6%
| Breast cancer diagnosed <40 yrs
Janezic et al, 1999^148^ | Population-based (US) | O | N | FH-NS | 107 | 2 | | | 1.9%
King et al, 2003^134^ | Cancer centers (US) | B | Y | FH-NS | 1,008 | 67 | 36 | 103 | 6.9% | 3.7% | 10.3%
| AJ
King et al, 2003 | Cancer centers (US) | B | Y | FH-NS | 105 | 26 | 11 | 37 | 24.0% | 10.0% | 35.0%
| AJ, age < 40 yrs
King et al, 2003 | Cancer centers (US) | B | Y | FH-NS | 135 | 12 | 10 | 22 | 9.0% | 7.0% | 16.0%
| AJ, age: 40–44 yrs
King et al, 2003 | Cancer centers (US) | B | Y | FH-NS | 187 | 11 | 4 | 15 | 6.0% | 2.0% | 8.0%
| AJ, age: 45–49 yrs
King et al, 2003 | Cancer centers (US) | B | Y | FH-NS | 305 | 15 | 6 | 21 | 5.0% | 2.0% | 7.0%
| AJ, age: 50–59 yrs
King et al, 2003 | Cancer centers (US) | B | Y | FH-NS | 276 | 2 | 6 | 8 | 0.8% | 2.0% | 2.8%
| AJ, age: > 60 yrs
King et al, 2003 | Cancer centers (US) | B | Y | FH-NS | 322 | 23 | 14 | 37 | 7.1% | 4.3% | 11.5%
| AJ, age: 40–49 yrs
King et al, 2003 | Cancer centers (US) | B | Y | Hgh | 350 | 34 | 16 | 50 | 9.7% | 4.6% | 14.3%
| AJ, FH with breast cancer
King et al, 2003 | Cancer centers (US) | B | Y | Mod | 658 | 33 | 20 | 53 | 5.0% | 3.0% | 8.0%
| AJ, Non - FH in 1 degree relatives
Langston et al, 1996^142^ | Population-based (US) | B | N | FH-NS | 80 | 6 | | | 7.5%
| Age: < 35 yrs
Langston et al, 1996 | Population-based (US) | B | N | Mod | 41 | 4 | | | 9.8%
| Age: < 35 yrs; FH
Langston et al, 1996 | Population-based (US) | B | N | Avg | 39 | 2 | | | 5.1%
| Age: < 35 yrs; Non-FH
Malone et al, 2000^143^ | Population-based (US) | B | N | FH-NS | 203 | 12 | 7 | 19 | 5.9% | 3.4% | 9.4%
| Age: < 35 yrs
Malone et al, 2000 | Population-based (US) | B | N | FH-NS | 45 | 5 | 2 | 7 | 11.1% | 4.4% | 15.6%
| Age: < 30 yrs
Malone et al, 2000 | Population-based (US) | B | N | FH-NS | 158 | 7 | 5 | 12 | 4.4% | 3.2% | 7.6%
| Age: 30–34 yrs
Malone et al, 2000 | Population-based (US) | B | N | Avg | 104 | 2 | 1 | 3 | 1.9% | 1.0% | 2.9%
| Age: < 35 yrs, Non-FH
Malone et al, 2000 | Population-based (US) | B | N | Mod | 38 | 4 | 1 | 5 | 10.5% | 2.6% | 13.2%
| Age: < 35 yrs, FH
Malone et al, 2000 | Population-based (US) | B | N | Hgh | 4 | 1 | 2 | 3 | 25.0% | 50.0% | 75.0%
| Age: < 35 yrs, FH
Malone et al, 2000 | Population-based (US) | B | N | Mod and Hgh combined | 225 | 16 | 11 | 27 | 7.1% | 4.9% | 12.0%
| Age: < 45 yrs, FH: 1st-degre
Malone et al, 2000 | Population-based (US) | B | N | Mod | 206 | 14 | 7 | 21 | 6.8% | 3.4% | 10.2%
| Age: < 45 yrs, FH: 1st-degree
Malone et al, 2000 | Population-based (US) Age: < 45 yrs, FH: ≥ 1st-degree breast cancer | B | N | Hgh | 19 | 2 | 4 | 6 | 10.5% | 21.1% | 31.6%
Modan et al, 2001^127^ | Population based case-control study (Israel) | O | Y | FH-NS | 596 | 182 | 64 | 244 | 30.5% | 10.7% | 40.9%
| AJ
Moslehi et al, 2000^135^ | Hospital-based (N. America /Israel) | O | Y | FH-NS | 208 | 57 | 29 | 86 | 27.4% | 13.9% | 41.3%
| AJ
Moslehi et al, 2000 | Hospital-based (N. America /Israel) | O | Y | Mod | 119 | 23 | 10 | 33 | 19.3% | 8.4% | 27.7%
| AJ, Non-FH
Moslehi et al, 2000 | Hospital-based (N. America /Israel) | O | Y | Hgh | 80 | 34 | 17 | 51 | 42.5% | 21.3% | 63.8%
| AJ, FH
Moslehi et al, 2000 | Hospital-based (N. America /Israel) | O | Y | FH-NS | 18 | 7 | 1 | 8 | 46.7% | 6.7% | 53.3%
| AJ, age: < 40 yrs
Moslehi et al, 2000 | Hospital-based (N. America /Israel) | O | Y | FH-NS | 54 | 24 | 2 | 26 | 44.4% | 3.7% | 48.1%
| AJ, age: 40–49 yrs
Moslehi et al, 2000 | Hospital-based (N. America /Israel) | O | Y | FH-NS | 43 | 15 | 8 | 23 | 34.9% | 18.6% | 53.5%
| AJ, age: 50–59 yrs
Moslehi et al, 2000 | Hospital-based (N. America /Israel) | O | Y | FH-NS | 49 | 9 | 10 | 19 | 18.4% | 20.4% | 38.8%
| AJ, age: 60–69 yrs
Moslehi et al, 2000 | Hospital-based (N. America /Israel) | O | Y | FH-NS | 44 | 2 | 8 | 10 | 4.5% | 18.2% | 22.7%
| AJ, age: > 70 yrs
Newman et al, 1998^145^ | Population-based (US) | B | N | FH-NS | 211 | 3 | | | 1.4%
| Breast cancer, age: 20–74 yrs
Newman et al, 1998 | Population-based (US) Breast cancer, age: 20–74 yrs, white | B | N | FH-NS | 211 | 7 | | | 3.3%
| Adjusted for sampling probabilities
Oddoux et al, 1996^128^ | Cancer center study (US) | B | Y | Hgh | 107 | 28 | 7 | 35 | 26.2% | 6.5% | 32.7%
| AJ with FH, age: 20–80 yrs
Oddoux et al, 1996 | Cancer center study (US) | B | Y | Hgh | 61 | 16 | 4 | 20 | 26.2% | 6.6% | 32.8%
| AJ with FH, age: < 42 yrs
Oddoux et al, 1996 | Cancer center study (US) | B | Y | Hgh | 46 | 12 | 3 | 15 | 26.1% | 6.5% | 32.6%
| AJ with FH, age: > 42 yrs
Peto et al, 1999^29^ | Population-based Case Control Studies (UK) | B | N | FH-NS | 617 | 16 | 14 | 30 | 2.6% | 2.3% | 4.9%
| Age: <46 yrs
Peto et al, 1999 | Population-based Case Control Studies (UK) | B | N | Avg | 547 | 13 | 13 | 26 | 2.4% | 2.4% | 4.8%
| Age: <46 yrs
Peto et al, 1999 | Population-based Case Control Studies (UK) | B | N | Mod | 67 | 3 | 0 | 3 | 3.0% | 0.0% | 4.5%
| Age: <46 yrs
Peto et al, 1999 | Population-based Case Control Studies (UK) | B | N | Hgh | 3 | 0 | 1 | 1 | 0.0% | 33.3% | 33.3%
| Age: <46 yrs
Peto et al, 1999 | Population-based Case Control Studies (UK) | B | N | FH-NS | 254 | 9 | 6 | 15 | 3.5% | 2.4% | 5.9%
| Age: <36 yrs
Peto et al, 1999 | Population-based Case Control Studies (UK) | B | N | FH-NS | 363 | 7 | 8 | 15 | 1.9% | 2.2% | 4.1%
| Age: 36–45 yrs
Risch et al, 2001^133^ | Population-based (Canada) | O | N | FH-NS | 649 | 39 | 21 | 60 | 6.0% | 3.2% | 9.2%
| Age: 20–79 yrs
Risch et al, 2001 | Population-based (Canada) | O | N | Avg | 504 | 10 | 12 | 22 | 2.0% | 2.4% | 4.4%
| Non-FH
Risch et al, 2001 | Population-based (Canada) | O | N | Mod | 145 | 29 | 9 | 27 | 20.0% | 6.2% | 18.6%
| FH
Risch et al, 2001 | Population-based (Canada) | O | N | FH-NS | 96 | 3 | 1 | 4 | 3.1% | 1.0% | 4.2%
| Age: ≤ 40 yrs
Risch et al, 2001 | Population-based (Canada) | O | N | FH-NS | 136 | 21 | 4 | 25 | 15.4% | 2.9% | 18.4%
| Age: 41–50 yrs
Risch et al, 2001 | Population-based (Canada) | O | N | FH-NS | 165 | 9 | 7 | 16 | 5.5% | 4.2% | 9.7%
| Age: 51–60 yrs
Risch et al, 2001 | Population-based (Canada) | O | N | FH-NS | 252 | 6 | 9 | 15 | 2.4% | 3.6% | 6.0%
| Age: > 60 yrs
Risch et al, 2001 | Population-based (Canada) | O | Y | FH-NS | 19 | 4 | 1 | 5 | 21.1% | 5.3% | 26.3%
| AJ ethnicity
Robson et al, 1998^153^ | Hospital-based (US) | B | Y | FH-NS | 91 | 23 | 7 | 30 | 25.3% | 7.7% | 33.0%
| Jewish, breast cancer diagnosed < 42 yrs
Robson et al, 1998 | Hospital-based (US) | B | Y | Hgh | 66 | | | 27 | | | 40.9%
| Jewish, breast cancer diagnosed < 42 yrs
Robson et al, 1998 | Hospital-based (US) | B | Y | Mod | 25 | | | 3 | | | 12.0%
| Jewish, breast cancer diagnosed < 42 yrs
Satagopan et al, 2001^137^ | Hospital-based Memorial Hospital (NY) | B | Y | FH-NS | 305 | 22 | 7 | 29 | 7.2% | 2.3% | 9.5%
| AJ
Satagopan et al, 2001 | Hospital-based Memorial Hospital (NY) | B | Y | FH-NS | 28 | 8 | 0 | 8 | 28.6% | 0.0% | 28.6%
| AJ, age: < 40 yrs
Satagopan et al, 2001 | Hospital-based Memorial Hospital (NY) | B | Y | FH-NS | 66 | 8 | 2 | 10 | 12.1% | 3.0% | 15.2%
| AJ, age: 40–49 yrs
Satagopan et al, 2001 | Hospital-based Memorial Hospital (NY) | B | Y | FH-NS | 211 | 6 | 5 | 11 | 2.8% | 2.4% | 5.2%
| AJ, age: > 50 yrs
Satagopan et al, 2001 | Hospital-based Mount Sinai (NY) | B | Y | FH-NS | 268 | 10 | 8 | 18 | 3.7% | 3.0% | 6.7%
| AJ
Satagopan et al, 2001 | Hospital-based Mount Sinai (NY) | B | Y | FH-NS | 15 | 1 | 1 | 2 | 6.7% | 6.7% | 13.3%
| AJ, age: < 40 yrs
Satagopan et al, 2001 | Hospital-based Mount Sinai (NY) | B | Y | FH-NS | 82 | 3 | 3 | 6 | 3.7% | 3.7% | 7.3%
| AJ, age: 40–49 yrs
Satagopan et al, 2001 | Hospital-based Mount Sinai (NY) | B | Y | FH-NS | 171 | 6 | 4 | 10 | 3.5% | 2.3% | 5.8%
| AJ, age: > 50 yrs
Satagopan et al, 2001 | Hospital-based Montreal (Canada) | B | Y | FH-NS | 209 | 25 | 8 | 33 | 12.0% | 3.8% | 15.8%
| AJ
Satagopan et al, 2001 | Hospital-based Montreal (Canada) | B | Y | FH-NS | 28 | 9 | 1 | 10 | 32.1% | 3.6% | 35.7%
| AJ , Age: < 40 yrs
Satagopan et al, 2001 | Hospital-based Montreal (Canada) | B | Y | FH-NS | 56 | 8 | 1 | 9 | 14.3% | 1.8% | 16.1%
| AJ, age: 40–49 yrs
Satagopan et al, 2001 | Hospital-based Montreal (Canada) | B | Y | FH-NS | 125 | 8 | 6 | 14 | 6.4% | 4.8% | 11.2%
| AJ , age: > 50 yrs
Stratton et al, 1997^147^ | Hospital-based (UK) | O | N | FH-NS | 374 | 12 | | | 3.2%
| < 70 yrs
Stratton et al, 1997 | Hospital-based (UK) | O | N | Avg | 345 | 6 | | | 1.7%
| < 70 yrs, Non-FH of ovarian cancer
Stratton et al, 1997 | Hospital-based (UK) | O | N | Mod | 29 | 6 | | | 20.7%
| < 70 yrs, FH of Ovarian cancer
Struewing et al, 1997^11^ | Population - based (US) | B | Y | FH-NS | 296 | 16 | 11 | 27 | 5.4% | 3.7% | 9.1%
| AJ, age: > 20 yrs
Struewing et al, 1997 | Population - based (US) | B | Y | FH-NS | 143 | 12 | 8 | 20 | 8.4% | 5.6% | 14.0%
| AJ, age: < 50 yrs
Struewing et al, 1997 | Population - based (US) | B | Y | FH-NS | 153 | 4 | 3 | 7 | 2.6% | 2.0% | 4.6%
| AJ, age: ≥ 50 yrs
Sutcliffe et al, 2000^146^ | UKCCCR Familial Ovarian | B | N | Hgh | 112 | | | 55 | | | 49.1%
| Cancer Register FH: ≥ 2 ovarian cancers
Warner et al, 1999^138^ | Hospital-based (Canada) | B | Y | FH-NS | 412 | 34 | 15 | 48 | 8.3% | 3.6% | 11.7%
| AJ
Warner et al, 1999 | Hospital-based (Canada) | B | Y | FH-NS | 3 | 1 | 0 | 1 | 33.3% | 0.0% | 33.3%
| AJ, age: 20–29 yrs
Warner et al, 1999 | Hospital-based (Canada) | B | Y | FH-NS | 27 | 10 | 2 | 12 | 37.0% | 7.4% | 44.4%
| AJ, age: 30–39 yrs
Warner et al, 1999 | Hospital-based (Canada) | B | Y | FH-NS | 134 | 16 | 8 | 23 | 11.9% | 6.0% | 17.2%
| AJ, age: 40–49 yrs
Warner et al, 1999 | Hospital-based (Canada) | B | Y | FH-NS | 111 | 5 | 4 | 9 | 4.5% | 3.6% | 8.1%
| AJ, age: 50–59 yrs
Warner et al, 1999 | Hospital-based (Canada) | B | Y | FH-NS | 137 | 2 | 1 | 3 | 1.5% | 0.7% | 2.2%
| AJ, age: > 60 yrs
Warner et al, 1999 | Hospital-based (Canada) | B | Y | Mod | 273 | 11 | 4 | 15 | 4.0% | 1.5% | 5.5%
| AJ, Non-FH

AJ, Ashkenazi Jewish; FH, family history; FH-NS, family history non-selected; UKCCCR, United Kingdom Coordinating Committee on Cancer Research.

* Average risk (Avg), no first-degree relatives with breast or ovarian cancer; moderate risk (Mod), one first-degree relative with cancer or AJ without a first-degree relative with cancer; high risk (Hgh), two or more first-degree relatives with cancer or AJ with one or more first-degree relatives with breast or ovarian cancer.