# Appendix H. Quality Ratings of Genetic Counseling Studies

Author, year | Study Design | Random assignment? | Allocation concealed? | Groups similar at baseline? | Eligibility criteria specified? | Blinding: outcome assessors, care provider, patient? | Intention-to-treat analysis? | Maintenance of comparable groups? | Reporting of attrition, contamination, etc.? | Differential loss to follow-up or overall high loss to follow-up? | Quality rating | External validity
Bowen et al, 2004^38^ | RCT | Yes | Yes | Yes | Yes | N/A | NR | Yes | Yes | 1% loss genetic counseling | Fair | Women in general public with breast cancer
| | | | | | | | | | 4% loss psychosocial counseling
| | | | | | | | | | 1% loss control
Bowen et al, 2002^39^ | RCT | Yes | NR | Yes | Yes | N/A | No | Yes | Yes | 8% loss psychosocial counseling | Fair | Women in Seattle area with lower risk of breast cancer
| | | | | | | | | | 10% loss genetic counseling
| | | | | | | | | | 10% loss control
Burke et al, 2000^40^ | RCT | Yes | NR | Yes | Yes | N/A | NR | Yes | Yes | 3% loss counseling | Fair | Women in Seattle area with intermediate family history of breast cancer
| | | | | | | | | | 8% loss control
Cull et al, 1998^41^ | RCT | Yes | Yes | Yes | Yes | N/A | NR | Yes | Yes | 24% loss video | Good | Women from 4 Scottish cancer family clinics
| | | | | | | | | | 37% loss control
Green et al, 2004^120^ | RCT | Yes | N/A | Yes | Yes | N/A | NR | Yes | Yes | 26% loss overall at 6 month follow-up | Good | Women from 6 U.S. medical center clinics offering genetic counseling
Lerman et al, 1999^42^ | RCT | Yes | NR | Yes | Yes | N/A | NR | No | Yes | 49% loss overall | Fair | Georgetown University Medical Center and Washington Hospital Center
| | | | | | | | | | (32% loss Causasian; 51% loss African American)
Lerman et al, 1996^43^ | RCT | Yes | NR | Yes | Yes | Outcome assessors blind only | NR | Yes | Yes | 12% loss overall 3-month telephone survey | Fair | Cancer treatment centers
| | | | | | | | | | 37% loss overall 3-month mail survey
Lerman et al, 1995^44^ | RCT | Yes | NR | Yes | Yes | Outcome assessors blind only | No | Yes | Yes | 12% loss overall | Fair | Fox Chase Cancer Center and Duke Comprehensive Cancer Center
Lobb et al, 2002^118^ | RCT | Yes | Yes | Yes | Yes | N/A | Yes | Yes | Yes | 18% loss overall | Good | 10 familial cancer clinics in 4 Australian states
Watson et al, 1998^119^ | RCT | Yes | Yes | Yes | Yes | N/A | Yes | Yes | Yes | 7% loss overall 1-month follow-up | Good | Women with a family history of breast cancer attending two London genetic clinics
| | | | | | | | | | 21% loss overall 6-month follow-up

NR, not reported; RCT, randomized controlled trial.