# Appendix G. Evidence Table of Genetic Counseling Studies

Author, year | Purpose | N | Population / Setting | Inclusion / Exclusion criteria | Family history / Risk level definition | Interventions | Results
Bowen et al, 2004^38^ | To test the effects of two types of breast cancer risk counseling (group psychosocial or individual genetic) on perceived risk, negative affect, and worry about breast cancer | 799 | Recruitment from among family members with breast cancer and through notices in local electronic and print outlets. Recruitment completed in 8 months. Women with a range of actual breast cancer risk levels were included. | [underlined: Inclusion:]; 1 women aged 18–74; 2 at least one relative with breast cancer; 3 no personal history of breast or ovarian cancer; 4 no family history consistent with a BRCA mutation for breast cancer risk; 5 living within 60 mile radius of research center; 6 willingness to complete research activities; 7 completed and returned baseline questionnaire | Family history: Self-report of any family history of breast cancer Risk level: Calculated by use of Gail and Claus models, along with population data | Telephone screening survey to determine eligibility, followed by mailed baseline survey. Those who returned completed surveys were randomized to individual genetic counseling (IGC), group psychosocial counseling (PC), or a delayed intervention control group. | Perceived risk decreased by 50% for participants in the two counseling groups relative to control (p<0.01). Cancer worry decreased in both counseling groups by one scale point (p<0.05). There were no differential effects of counseling type on perceived risk or cancer worry. Those in the PC group reported more anxiety change than those in the other groups. Depression was not impacted by study group.
| | | | | | [underlined: ICG]: Telephone contact with genetic counselor to review pedigree information. One 2-hour session following protocol based on standard genetic practice. Letter sent to participant within 2 weeks summarizing the session.
| | | | | | [underlined: PC]: Group of 4–6 participants met for four, 2-hour sessions led by a trained health counselor. Each participant received her own risk assessment sheet, personalizing the group discussion to her own risk status. Main topics: risk assessment and perception, screening, stress management and problem solving, and social support.
| | | | | | For ICG and PC, brief survey on reactions to counseling within 4 weeks of last counseling contact. Mailed 2nd assessment 6 months after randomization, with a reminder call and offer of phone completion to those who did not return survey after 2 weeks.
Bowen et al, 2002^39^ | To test the effects of breast cancer risk on interest in genetic testing in women who have a family history of breast cancer | 721 | Women recruited from the Seattle area—see Bowen et al, 1999.^243^ All volunteered after seeing a notice, hearing about the study from a network or through a relative with cancer. | [underlined: Inclusion:]; 1 women aged 18–74; 2 lived within 60 miles of research center; 3 agreed to participate in counseling & complete questionnaires; 4 at least 1 relative affected by breast cancer | Family history: Close relatives affected by breast cancer included grandmothers, mothers, sisters, and aunts | Telephone screening survey to determine eligibility, followed by mailed baseline survey. Those who completed survey randomly assigned to individual genetic counseling (IGC), psychosocial group counseling (PGC) or control group (CG). Mailed follow-up survey 6 months after randomization. | Counseling about breast cancer risk slightly changed level of interest in genetic testing for breast cancer risk in women with a family history. Those who participated in counseling were less interested in genetic testing and less likely to view themselves as good candidates. Stigma and access beliefs about genetic testing were related to the effect of counseling on candidacy judgment. As women gained more information, they were less likely to want to participate in testing.
| | | | [underlined: Exclusion:] more than 1 close relative affected by breast cancer | Risk level: Gail and Claus scores, along with population data | [underlined: IGC]: Phone call to review pedigree information followed by a single 2-hour counseling session. Subject given information on her own risk for breast cancer using Gail and Claus scores along with population data. Information given on genetic testing, current knowledge about nonhereditary risk factors, and current screening techniques. Summary letter provided.
| | | | | | [underlined: PGC]: Four, 2-hour group meetings with 4–6 women led by a health counselor. Included: risk assessment and perception, education, stress management, problem-solving and social support. Personal risk for breast cancer, interpretation and appropriate screening provided privately to subjects.
| | | | | | [underlined: CG]: Offered choice of counseling modality after the final follow-up.
Burke et al, 2000^40^ | To assess whether modified traditional genetic counseling causes women with an intermediate risk of breast cancer to have a more realistic view of their risk, of genetic testing, and to decrease breast cancer worry | 793 | Sources for solicitation include women who live within 60 miles of Seattle: 2 studies at Fred Hutchinson Cancer Research Center, an oncologist's practice at University of Washington, mass media announcements. | [underlined: Inclusion:]; 1 between 18–74 years old; 2 lives within 60 miles of Seattle; 3 has at least 1 biological relative who has been diagnosed with breast cancer | Intermediate family history of breast cancer: 1 or more biological relative(s) with breast cancer but whose pedigree suggests a low likelihood of autosomal dominant transmission. | Random assignment to 3 groups: individual genetic counseling (120 women), psychosocial group counseling (113 women), control (123 women). | Significant differences between counseling and control groups in mean perceived risk of breast cancer (F=27.9, p<0.009). Significant differences over time in perceived risk for the counseling group (F=65.9, p<0.001). Interaction between group and time for perceived risk was significant (F=50.6, p<0.001). Low over-estimators of breast cancer risk reduced risk estimates by an average of 19 percentage points after counseling, compared with high over-estimators who reduced risk estimates by an average of 36 percentage points (F=13.41, p<0.00001). After counseling, those who perceived themselves as candidates for testing decreased from 82% to 60% and interest in testing was reduced from 91% to 60%. 82 (70%) liked the counseling very much. 65 (56%) found the counseling very useful and 26 (22%) found it moderately useful. After receiving risk estimates, 39 (33%) were a lot less worried and 37 (32%) were a little less worried.
| | | | [underlined: Exclusion:]; 1 has personal history of breast or ovarian cancer; 2 has family history indicative of autosomal dominant inheritance of breast cancer | Family history indicative of autosomal dominant inheritance of breast cancer: 2 or more 1st degree or one 1st degree and one 2nd degree relative with either breast cancer before age 50 or ovarian cancer at any age, or at least 2 paternal 2nd degree relatives with either breast cancer before age 50 or ovarian cancer at any age. The Claus model showed that these women would have at least a 20% breast cancer risk by age 79. | Psychosocial group counseling details not included in this paper.
| | | | | | Adapted genetic counseling protocol for women with intermediate risk included pre-counseling
Cull et al, 1998^41^ | To evaluate use of video for education on the genetic basis of breast cancer and on strategies for breast cancer risk management in a breast cancer family clinic | 159 | A consecutive series of women newly referred to the breast cancer family clinic were invited by mail to participate. 24% of the video before (VB) and 30% of the video after (VA) group were referred by another hospital clinic. One subject in each group had been referred from another genetic clinic. The remaining were referred by general practitioners. | None reported | Not reported | Subjects sent information about study with initial clinic appointment 4 weeks before the appointment. They were asked to return baseline questionnaires and forms within 2 weeks if wanting to participate. Those who did so were randomized either to the VB group, and were sent a copy of the educational video about 10 days before the clinic consultation, or to the VA group, taking the video home after the post-clinic assessment. Clinic consultation: individual meeting with geneticist to discuss individual risk and with breast surgeon to discuss risk management. Clinicians noted session length and rated assessment of it. Post-clinic assessment included completion of instruments. Follow-up assessment by mail 4 weeks later. | [underlined: Duration of Consultation]: VB group spent less time with surgeon (mean 11.8 min vs 14.6, p< 0.05), but their time with geneticist was not significantly shorter.
| | | | | | | [underlined: Risk Assessment]: No significant difference between VB or VA in accuracy of estimate at baseline. VB retained accuracy from clinic to follow-up. VA were more likely to underestimate at follow-up (p< 0.05).
| | | | | | | [underlined: Understanding of Risk Information]: Subjective: At baseline and at follow-up, no significant difference.
| | | | | | | [underlined: Objective]: VB had higher scores (p< 0.01) and a higher proportion of correct responses to more items. Follow-up: no significant differences after adjusting for education level (t =0.34).
| | | | | | | [underlined: Emotional Distress]: No significant difference in groups in anxiety or distress levels.
| | | | | | | [underlined: Use of Video and Family Discussion]: VB: 94% watched video at least 1× from start to finish. 76% reported it offered new information. VA: 41/42 who gave follow-up data watched the video at least once and 41% of them said it gave new information. In both VA and VB, most (66% and 65%, respectively) watched it alone and most discussed it with a partner.
Green et al, 2004^120^ | To compare effectiveness of a computer-based decision aid with standard genetic counseling in educating women about genetic testing for BRCA1 and BRCA2 | 211 | Subjects were enrolled from outpatient clinics at 6 US medical centers offering cancer genetic counseling for women with personal or family histories of breast cancer. | [underlined: Inclusion:]; 1 referred for genetic counseling for evaluation of personal or family history of breast cancer; 2 able to read, write, and speak English | Low risk: less than 10% chance of carrying a deleterious BRCA1 or BRCA2 mutation defined by BRCAPRO model | Separate computer-generated randomization lists for low-risk and high-risk individuals at each study site. Randomized to counselor group or interactive computer-based educational program. Baseline questionnaire completed on or just before the day of first appointment. Assessments at 1 and 6 months after study visit.; 1 Counseling group: standard topics covered that were consistent with current practice guidelines and with information presented in the computer program. Individualized risk estimates provided on likelihood of carrying a genetic mutation and of developing breast cancer. Psychosocial component included to address emotional concerns if presented.; 2 Computer-based education program: interactive, multimedia CD-ROM-based decision aid designed to educate women about breast cancer, heredity, and benetfits and limitations of genetic testing. Self-paced and user-driven. Participants used for an average of 45–60 minutes, and then completed post-intervention measures, followed by counseling. | [underlined: Knowledge:] Both genetic counseling and the computer-based education program increased knowledge scores, regardless of risk status (p<0.001). Change in knowledge was greater in the computer group among women at low risk of carrying a mutation (p=0.03).
| | | | [underlined: Exclusion:]; 1 previous genetic counseling or testing for inherited breast cancer susceptibility | High risk: 10% or higher chance of carrying deleterious BRCA1 or BRCA2 mutation defined by BRCAPRO model | | [underlined: Anxiety:] Mean state anxiety scores were within normal range for both groups at baseline and after either intervention, regardless of risk status. The counseling group had lower anxiety scores post-treatment (p=0.001). Anxiety scores did not change significantly after using the computer-based program, but were lower after use of both counseling and the computer-based program.
| | | | | | | [underlined: Risk perception:] Perception of absolute risk of breast cancer decreased after either intervention among all participants (p<0.001). Absolute breast cancer risk perception was lower after using the computer-based program (p=0.006). For low-risk women, genetic risk perception was lower after counseling in both interventions (p<0.001).
| | | | | | | [underlined: Genetic testing intention:] Intention to participate in testing decreased after either intervention for low-risk but not high-risk women (p<0.001 after counseling, p<0.05 after computer-based education).
| | | | | | | [underlined: Decision satisfaction:] The counseling group had lower mean scores on a decisional conflict scale (p=0.04), and, in low-risk women, higher mean scores on a satisfaction-with-decision scale (p=0.001).
Lerman et al, 1999^42^ | To investigate racial differences in response to two alternate pretest education strategies for BRCA1 genetic testing: a standard education model and an education plus counseling model | 581 | Subjects were recruited from two cancer centers (Georgetown University Medical Center or Washington Hospital Center). | [underlined: Inclusion:] Caucasian and African American women with a family history of breast cancer or ovarian cancer | At least one 1st degree relative affected with breast cancer and/or ovarian cancer | Randomly assigned by computer to control group (wait list control), education only group, or education + counseling group at the end of baseline telephone interview.; 1 Baseline phone interview for demographic information.; 2 Education only: topics discussed included individual risk factors for breast cancer and ovarian cancer and patterns of inheritance for breast and ovarian cancer susceptibility. Subjects given qualitative estimates of their risk of developing breast cancer and ovarian cancer. Pedigrees were reviewed. Potential benefits, limitations, and risks of genetic testing for inherited breast cancer and ovarian cancer susceptibility also reviewed.; 3 Education + counseling: provided the same education and materials described above. Subjects guided through a set of questions that explored personal issues related to cancer and genetic testing. Subjects discussed the emotional impact of having a family history of cancer, psychosocial implications of genetic testing for inherited breast cancer and ovarian cancer susceptibility, anticipated reactions to a positive and negative test result, and intentions to communicate test results to family members and friends. | [underlined: Overall:] African American women were found to differ significantly from Caucasian women in the effects of the interventions on testing intentions and provision of a blood sample. Effects were independent of socioeconomic status and referral mechanism.
| | | | [underlined: Exclusion:] personal history of cancer (except basal cell or squamous cell skin cancers) | | | [underlined: Genetic testing intention]: Family history and baseline genetic testing intentions both made significant independent contributions to 1-month genetic testing intentions. Women with stronger family history of cancer had greater increases in intentions. Only in African American, education + counseling led to greater increases in intentions than education only (p=0.003).
| | | | | | | [underlined: IES scores:] All groups evidenced a reduction in distress from baseline to 1 month. However, this decrease, although not a significant difference, was smallest among African American women who received education + counseling.
Lerman et al, 1996^43^ | To evaluate the impact of individualized breast cancer risk counseling among women with a family history of breast cancer | 239 | Subjects were sisters, daughters, and/or mothers of women under treatment for breast cancer at a cancer treatment center. | [underlined: Inclusion:] women aged 35 and older living within a 6-hour drive of the clinic with a positive history of breast cancer in at least one first-degree relative | Family history: At least one 1st degree relative with breast cancer Risk level: Based on Gail model | Women in treatment for breast cancer identified sisters, daughters, and/or mothers who were then sent an introduction letter. All who did not decline by phone participated 2 weeks later in a phone interview baseline assessment of demographics, risk factors, coping styles, and distress. Completers were given information about the study and were asked to participate. They were randomized to Individualized Breast Cancer Risk Counseling (BCRC) or General Health Counseling (GHE), the control condition. Immediately before the 1-hour intervention, participants completed self-report questionnaires. After 3 months, a follow-up phone interview assessed risk perceptions and screening practices. Participants were then asked to complete a set of self-report questionnaires. | After controlling for education level, women who received BCRC had significantly less breast cancer specific distress at 3-month follow-up compared with those in the control (GHE) group (p<0.01). There was no difference between the groups in general distress. Psychological benefits of BCRC were greater for women with less formal education (p<0.01). In both groups, women with monitoring coping styles had increased general distress from baseline to follow-up (p<0.01).
| | | | [underlined: Exclusion:] prior diagnosis of cancer (except basal or squamous cell skin cancers)
Lerman et al, 1995^44^ | To study effect of individualized breast cancer risk counseling | 438 | Subjects identified by relatives under treatment for breast cancer at either Fox Chase Cancer Center or Duke Comprehensive Cancer Center. | [underlined: Inclusion:]; 1 women aged 35 and older; 2 family history of breast cancer | At least one 1st degree relative with breast cancer | Randomized to control group (genetic health counseling) or study group (breast cancer risk counseling) | Breast cancer preoccupation: IES average score on measure of breast cancer preoccupation was 6.9+ 0.71 (means +SE). No significant baseline difference in risk comprehension between groups; however, significant change in risk comprehension at 3-month follow-up due to movement in risk-counseling group from overestimation to accurate or underestimation.
| | | | [underlined: Exclusion:]; 1 personal history of cancer; 2 younger than 35 | Breast cancer risk estimates for individual women were calculated using subject's Gail model variables and estimated the lifetime probability of developing breast cancer, the 95% CIs, and the estimated lifetime risk for a woman of the same age with the lowest risk of disease. | Study group: 1) discussion of individual factors contributing to elevated risk, 2) presentation of individualized risk data, 3) recommendations for annual mammography and clinical breast exams, 4) instruction in breast self-exam Control group: 1) interview assessment of current health practices, 2) age-specific recommendations for variety of cancer screening tests, 3) encouragement to quit smoking, 4) suggestions for reducing dietary fat to 30% or less, 5) recommendations for regular aerobic exercise
Lobb et al, 2002^118^ | To assess with validated measures of psychological outcome, the use of an audiotape in genetic counseling in a large sample of affected and unaffected women attending a familial cancer clinic | 244 | Consecutive women attending any one of 10 familial cancer clinics in four Australian states. Quota sampling used to balance sample between affected and unaffected women. | [underlined: Exclusion:]; 1 unable to give informed consent; 2 evidence of severe mental illness; 3 limited literacy in English; 4 younger than age 18 | Number of 1st and 2nd degree relatives who had developed breast or ovarian cancer at baseline | Women invited to participate when they telephoned familial cancer clinic to make an appointment. Women were asked to complete mailed baseline questionnaire sent 2 weeks before clinic appointment. Double-blind randomization occurred in clinic immediately after the genetic counseling. All counseling sessions were audiotaped and women were then randomized to receive the audiotape (T group) or not (NT group). Follow-up questionnaire mailed 3 weeks after counseling. | In the T group, affected women (p = 0.03) and women with increased generalized anxiety at baseline (p = 0.01) were significantly more likely to listen to the tape. Women who were more depressed (p = 0.06) and with lower breast cancer genetics knowledge (p = 0.07) were more likely to listen to the tape. Unaffected women in the T group were less likely to be accurate in their risk perception at follow-up (p = 0.05) than unaffected women in the NT group. The tape had no effect on risk accuracy when analysis included only those inaccurate at baseline. There was a trend for those in the T group to have improved scores on depression at follow-up (p = 0.06). In a repeated analysis with only those who listened to the tape, those in the T group had more anxiety reduction (p = 0.02) and more depression reduction (p = 0.01). Coping style (monitoring vs. blunting) did not influence likelihood of listening to the tape or response to the tape.
Watson et al, 1998^119^ | To look at recall of risk information after genetic counseling, and to determine impact of receiving an audiotape of the genetic consultation on level of recall, cancer-related worry, and uptake of risk management methods | 135 | First time attendees at the cancer family clinics of 2 London hospitals—Royal Marsden, Sutton and London, and St. George's Hospitals. | [underlined: Inclusion:]; 1 women with a family history of breast cancer; 2 first visit to genetic clinic; 3 never having been clinically affected with cancer; 4 no known mental illness; 5 aged 18 or over | Not reported | Randomized to consultation plus audiotape (n=60) or consultation only (n=55) (randomized at clinic immediately after consultation to minimize bias). All subjects were referred for genetic counseling with a clinical geneticist who provided a consultation, including pedigree based on risk calculation and information regarding management options based on risk level. All were offered instructions on self-exam and clinical exam as part of consultation. In addition to consultation, the case group received an audiotape of the consultation. | [underlined: Overall: GHQ-12 scores:] For combined groups, median score was 1 (range 0–11). 36 subjects had a score indicative of psychological morbidity (>3) at baseline and 31 at 1-month and 6-month follow-ups.
| | | | | | | [underlined: CWS scores:] For both groups median score was 11 (range 6–22). CI=10–12 for cases and CI=10–11 for controls; mean 11.14 (SD 3.23) for cases and mean 11.39 (SD 3.37) for controls. Scores fell in subjects given a tape of consultation from median 11 at baseline to 10 at 1 month, then 9 at 6 months.
| | | | | | | [underlined: Relative risk scores:] At 1-month follow-up 41% accurately recalled their risk of developing cancer, 25% overestimated, 11% underestimated, 23% didn't know/didn't remember. Results suggest that risk figure, regardless of accuracy, doesn't reflect more general view about risk compared with average women. Risk figure given as odds ratio compared with other formats (percentage or descriptive terms): odds ratio—71% were accurate in recall compared with 25% when given in other formats.
| | | | | | | [underlined: Risk questionnaire scores:] Usefulness of information rated on a visual analog scale. Average ratings were high, ranging from 8.5 (population risk) to 9.1 (risk of gene in family). Risk of gene in family, lifetime risk, and risk < age 50 were rated significantly more useful than population risk, risk of no cancer by age 50, and risk of disease over next 5 years.
| | | | | | | [underlined: Medical management uptake:] No significant correlation between cancer worry change scores and either level of breast clinical exam (p=0.8) or mammography (p=0.8), no difference between cases and controls for rate of self-exam, doctor exam, or mammography at 6-month follow-up, no difference between groups for other health behaviors unaffected by whether consultation tape was received or not.

CWS, Cancer Worry Scale; GHQ-12, General Health Questionnaire (12-item); IES, Impact of Events Scale.