# Appendix F. Reviewers

Content Experts | Wylie Burke, MD, PhD
| Professor and Chair, Department of Medical History & Ethics
| Adjunct Professor, Medicine; Epidemiology
| University of Washington
| Mary Daly, MD, PhD
| Senior Member, Population Science Division
| Fox Chase Cancer Center
| Kathy Helzlsouer, MD, MHS
| Professor, Epidemiology & Oncology
| Department of Epidemiology
| John Hopkins University
| Monica McClain, PhD
| Associate Director, Biometry and Epidemiology
| Foundation for Blood Research
| Mark Robson, MD
| Clinical Genetics Service
| Memorial Sloan Kettering Cancer Center
| Stephen Taplin, MD
| Applied Research Program
| National Cancer Institute
| Donald Berry, PhD
| Professor, Chair
| Department of Biostatistics
| The University of Texas
| MD Anderson Cancer Center

Federal Agencies | Ralph J. Coates, PhD
| Associate Director for Science
| Division of Cancer Prevention and Control
| Centers for Disease Control and Prevention
| Linda Kinsinger, MD, MPH
| Assistant Director
| VA National Center for Health Promotion and Disease Prevention
| Barnett Kramer, MD, MPH
| Associate Director for Disease Prevention
| National Institutes of Health
| David Atkins, MD, MPH
| Chief Medical Officer
| Center for Outcomes and Evidence
| Agency for Healthcare Research and Quality
Professional Societies or Organizations | Mary F. Mitchell
| Director
| Professionalism and Gynecologic Practice
| American College of Obstetricians and Gynecologists
| Herbert F. Young, MD, MA
| Director
| Scientific Activities Division
| American Academy of Family Physicians