# Appendix D. Statistical Methods

The meta-analysis of penetrance was based on Bayes' theorem and stratified by cancer type (breast or ovarian), risk group (average, moderate, and high), and age whenever enough data were available. The penetrance of BRCA mutations is the probability of developing cancer given that a clinically significant BRCA mutation is present. Let D ^+^ denote “individual has cancer,” D ^-^ denote “individual does not has cancer,” G denote “individual has a clinically significant BRCA mutation,” penetrance is then denoted as P( D ^+^│ G). By Bayes' theorem, penetrance is given by:

where P( D ^-^ ) = 1 - P( D ^+^). In our analysis, we assume P( D ^+^) is fixed. For the average risk group, the estimate of P( D ^+^) from Surveillance, Epidemiology, and End Results (SEER) data is used in the calculation of penetrance. When family history is present, the estimate of P( D ^+^) is obtained by multiplying the SEER estimate by the relative risk of cancer with a positive family history. P( G│ D ^+^) and P ( G│ D ^-^) are the prevalences of BRCA mutations from the cancer-affected and cancer-unaffected populations respectively, and estimated from different studies using the meta-analysis approach as described above.

The 95% confidence interval of P( D ^+^│ G) is calculated as follows. Modifying equation (1), we have:

then,

Assuming that P( G│ D ^+^) and P ( G│ D ^-^) are independent with each other, standard calculation using delta-method shows:

Usually,

is assumed to be normally distributed and the 95% confidence interval of

is given as

The 95% confidence interval of P( D ^+^│ G) is obtained by converting the above interval back to the original scale.

For some risk groups, there are no data from genetic testing studies to estimate P( G│ D ^-^) and we used the best point estimates available in the literature. However, standard errors associated with the point estimates are usually not available. Under such conditions, the second part of (3) on the right hand side would be zero, and the 95% confidence interval for the penetrance would be underestimated.

Equation (1) provides the formula to calculate penetrance for cases in general. It is easy to extend (1) to calculate penetrance of BRCA mutations by a particular age or with a positive family history. For example, if we are interested in penetrance of BRCA mutations by Age x, we substitute D ^+^ by D ^+^ by Age x in equation (1)

In this analysis, we assume

In our analysis, we calculated penetrance of breast cancer to ages 40 and 75 and ovarian cancer to ages 50 and 75 to be consistent with how age was considered by the studies. For penetrance of BRCA mutations when a positive family history is present,

We conducted a sensitivity analysis in the average and moderate risk groups by calculating penetrance two ways by including and excluding studies of women with family history of breast or ovarian cancer. Calculation of 95% CI for penetrance in (4) and (5) is similar to that described above, with appropriate substitution of terms.