# Appendix B. Inclusion/Exclusion Criteria By Key Question

## Key Question 2 (Ethical, Legal, Social Implications)

Include | Randomized controlled trial
| Comparative study (cohort, case-control or observational study) with 50 or more subjects
Exclude | Not applicable to U.S. primary care setting
| Information not relevant (dated, off-topic)
| Anecdotal only, no data
| Single case report, letter, commentary, opinion
| Overview, meta-analysis, or review with relevant information
| Practice standards or guidelines
| Legal, with case study or data
| Regulations or legislation
| Background
| Policy
| Cost
| Background

## Key Question 3a (Risk Assessment)

Include | Risk models
| Risk evaluation instrument
| Practice standards or guidelines
| Randomized controlled trial
| Comparative study (cohort, case-control or observational study) with 50 or more subjects
| Overview, meta-analysis, or review with relevant information
| Cost
Exclude | Not applicable to U.S. primary care setting
| Study limitations (small N, non-comparative, single case report)
| No data (commentary, letter, opinion)
| Information not relevant (dated, off-topic)

## Key Question 3b (Genetic Counseling)

Include | Randomized controlled trials
Exclude | Not applicable to U.S. primary care setting
| Study limitations (small N, non-comparative, single case report)
| No data (commentary, letter, opinion)
| Information not relevant (dated, off-topic)
| Comparative study (cohort, case-control or observational study) with 50 or less subjects
| Overview, meta-analysis, or review with relevant information
| Practice standards or guidelines
| Cost

## Key Question 3c (Genetic Testing)

Include | Genetic testing for heritable clinically significant BRCA1 and/or BRCA2 mutations (excludes tumor tissue only studies)
| Subjects from U.S., Canada, U.K., Australia, or Israel
| 50 or more subjects
Exclude | Risk model only
| No primary data included (include meta-analysis)
| Not BRCA1 or BRCA2
| Not breast or ovarian cancer
| No genetic testing
| Only 2^nd^ cancer at same site (risk of 2^nd^ contralateral cancer)
| Basic science only (studies of gene function or gene expression)
| Tumor tissue only study
| Linkage and/or segregation analysis (i.e., no testing for BRCA1 or BRCA2 mutations)

## Key Questions 5 and 6 (Interventions and Adverse Effects)

Include | Randomized controlled trial
| Comparative study (cohort, case-control or observational study) with 50 or more subjects
| Overview, meta-analysis, or review with relevant information
| Surveillance
| Chemoprevention
| Prophylactic surgery
| Cost
Exclude | Not applicable to U.S. primary care setting
| Study limitations (small N, non-comparative, single case report)
| No data (commentary, letter, opinion)
| Information not relevant (dated, off-topic)