# Appendix S. Sensitivity Analyses

Assumptions | Risk level | Risk level
| Moderate | High
Number of women screened | 100,000 | 100,000
Prevalence of clinically significant BRCA mutations (%)
BRCA1 | 0.82(0.53 – 1.28) | 6.42(1.13 – 29.09)
BRCA2 | 1.13(0.88 – 1.44) | 1.1(0.61 –1.98)
Penetrance of mutation to age 40/50 (%)
Breast cancer (to age 40 years)
BRCA1 | 5.03(1.85,12.97) | 6.88(1.92–21.78)
BRCA2 | 1.23(0.40–3.75) | 9.1(4.11–18.94)
Ovarian cancer (to age 50 years)^#^
BRCA1 | 14.16(9.17–21.23) | no data
BRCA2 | 1.79(0.88, 3.58) | no data
Penetrance of mutation to age 75 (%)
Breast cancer
BRCA1 | 38.83(27.26–51.80) | 44.14(11.47–82.82)
BRCA2 | 24.89(13.11–42.14) | 24.17(17.20–32.84)
Ovarian cancer^#^
BRCA1 | 31.49(21.91–42.96) | 21.67(4.84–60.07)
BRCA2 | 11.72(8.16 –16.56) | 44.57(28.06–62.37)
Risk reduction of SERMs to prevent all types of breast cancer, trials with mutation status unknown (RR=0.62; 0.46–0.83) | 0.38(0.17 – 0.54) | 0.38(0.17 – 0.54)
Risk of thromboembolic events from SERMs (% per year) | 0.096(0.036–0.156) | 0.096(0.036–0.156)
Risk of endometrial cancer from SERMs (% per year) | 0.036(0.00177 – 0.0709) | 0.036(0.00177 – 0.0709)
Proportion of candidates choosing SERMs (%) (not known) | uniform(5,50) | uniform(5,50)
Risk reduction of mastectomy to prevent breast cancer if BRCA mutation (RR=0; 0–0.36) | 0.91(0.64–1.00) | 0.91(0.64–1.00)
Risk of complications from mastectomy and reconstruction (% overall) (based on one study; range not known) | 21 | 21
Proportion of candidates choosing mastectomy (%) (not known) | uniform(5,20) | uniform(5,20)
Risk reduction of oophorectomy to prevent breast cancer if BRCA mutation (RR=0.32; 0.08–1.20) | 0.68(0.01–0.92) | 0.68(0.01–0.92)
Risk of complications from oophorectomy (% overall) (based on one study; range not known) | 5 | 5
Proportion of candidates choosing oophorectomy (%) (not known) | uniform(25,75) | uniform(25,75)
Risk reduction of oophorectomy to prevent ovarian cancer in BRCA mutation ((RR-0.15; 0.02–2.31) | 0.85 (0.01–0.99) | 0.85 (0.01–0.99)
Risk of complications from oophorectomy (% overall) (based on one study; range not known) | 5 | 5
Proportion of candidates choosing oophorectomy (%) (not known) | uniform(25,75) | uniform(25,75)
| Risk level | Risk level
Outcomes-benefits to age 40 | Moderate | High
Number of breast cancer cases expected among candidates if not undergoing treatment | 58(26–126) | 467(158,1707)
Number of breast cancer cases prevented among candidates taking SERMs (using overall risk reduction of 0.38) | 5.4(0.93–18.3) | 43(6.3–219)
NNS to prevent 1 case of breast cancer using SERMs | 18677(5466–108044) | 2344(456–15930)
NNT with SERMs to prevent 1 case of breast cancer | 92(37–273) | 44(11–164)
Number of breast cancer cases prevented among candidates undergoing mastectomy | 6.3(1.9–17.3) | 50(12–217)
NNS to prevent 1 case of breast cancer using mastectomy | 15988(5771–51294) | 1987(460–8076)
NNT with mastectomy to prevent 1 case of breast cancer | 37.1(16.7–85.4) | 17.8(4.8–54)
Number of breast cancer cases prevented among candidates if undergoing oophorectomy | 16.7(0.27–51.6) | 134(2.1 – 633)
NNS to prevent 1 case of breast cancer using oophorectomy | 5924(1940–371335) | 747(158–46855)
NNT with oophorectomy to prevent 1 case of breast cancer | 54(21.2 – 3463) | 27(6.3–1693)
Number of ovarian cancer cases expected among candidates if not undergoing treatment | 138(94–198) | No data
Number of ovarian cancer cases prevented among candidates undergoing oophorectomy | 51(0.62–107) | No data
NNS to prevent 1 case of ovarian cancer using oophorectomy | 1968(934–161826) | No data
NNT with oophorectomy to prevent 1 case of ovarian cancer | 17.7(11.1–1476) | No data
| Risk level | Risk level
Outcomes-benefits to age 75 | Moderate | High
Number of breast cancer cases expected among candidates if not undergoing treatment | 604(433–820) | 3465(1361 –5955)
Number of breast cancer cases prevented among candidates taking SERMs (using overall risk reduction of 0.38) | 58(11–143) | 306(51–971)
NNS to prevent 1 case of breast cancer using SERMs | 1739(697–8814) | 327(103 – 1945)
NNT with SERMs to prevent 1 case of breast cancer | 8.6(5.3–20.6) | 6.0(2.9–19.6)
Number of breast cancer cases prevented among candidates undergoing mastectomy | 67(26–128) | 360(105–894)
NNS to prevent 1 case of breast cancer using mastectomy | 1497(783–3801) | 278(112–952)
NNT with mastectomy to prevent 1 case of breast cancer | 3.5(2.5–5.6) | 2.4(1.3–6.3)
Number of breast cancer cases prevented among candidates if undergoing oophorectomy | 181(2.9–395) | 972(16–2710)
NNS to prevent 1 case of breast cancer using oophorectomy | 554(253–34512) | 103(37–6395)
NNT with oophorectomy to prevent 1 case of breast cancer | 4.9(3.0–327) | 3.6(1.6–223)
Number of ovarian cancer cases expected among candidates if not undergoing treatment | 393(302–499) | 1888(782–4357))
Number of ovarian cancer cases prevented among candidates undergoing oophorectomy | 146(1.8–286) | 668(7.9 – 2110)
NNS to prevent 1 case of ovarian cancer using oophorectomy | 687(350–56591) | 150(47 – 12658)
NNT with oophorectomy to prevent 1 case of ovarian cancer | 6.1(4.3–512) | 5.3(2.0 – 447)
| Risk level | Risk level
Outcomes-adverse effects | Moderate | High
Number of women taking SERMs | 544(119–1044) | 1893(292–9885)
Number of cases of thrombotic events due to SERMs | 0.52(0.088–1.24) | 2.59(0.22–10.1)
NNT with SERMs to cause one thrombotic event | 1042(641–2719) | 1042(641–2719)
Number of cases of endometrial cancer due to SERMs | 0.20(0.0068–0.54) | 0.98(0.019–4.14)
NNT with SERMs to cause one case of endometrial cancer | 2686(1228–15726) | 2686(1228–15726)
Number of women undergoing mastectomy | 247(102–424) | 897(201–4176)
Number of women with complications from | 52.0(21.4–89.0) | 188(42–877)
NNT with mastectomy to cause one complication | 5 | 5
Number of women undergoing oophorectomy | 990(490–1601) | 3651(901–16246)
Number of women with complications from oophorectomy | 49.5(24.5–80.0) | 183(45–812)
NNT oophorectomy to cause one complication | 20 | 20

NNS, number needed to screen; NNT, number needed to treat; SERMs, selective estrogen receptor modulators.