# Appendix R. Quality Ratings of Prophylactic Surgery Studies

Author, year | Design | Considers potential confounders? | Maintenance of comparable groups? | Loss to follow-up? | Measures equal, reliable, valid? | Clear definition of interventions? | Important outcomes considered? | Adjustment for confounders? | Quality rating for internal validity | Quality rating for external validity | Limitations
Mastectomy
Hartmann et al, 1999^201^ | Retrospective cohort with comparison group | Yes | Yes | No | Yes | Yes | Yes | Limited | Study design not included in USPSTF quality criteria | Highly selected women | No data on adverse events; small number of cases; potential ascertainment bias; one comparison group based on risk model
Hartmann et al, 2001^202^ | Retrospective cohort | Yes | Yes | No | Yes | Yes | Yes | Limited | Fair | Highly selected women | Small number of subjects with mutations; small number of cases; comparison group based on penetrance models
Meijers-Heijboer et al, 2001^70^ | Prospective cohort | Yes | Yes | No | Yes | Yes | Yes | Limited | Fair | Highly selected women | No data on adverse events; small number of cases
Rebbeck et al, 2004^71^ | Prospective & retrospective cohort with matched comparison group | Yes | Yes | No | Yes | Yes | Yes | Limited | Study design not included in USPSTF quality criteria | Highly selected women | No data on adverse events; potential biases with retrospective design
Oophorectomy
Rebbeck et al, 1999^72^ | Prospective & retrospective cohort with matched comparison group | Yes | Yes | No | Yes | Yes | Yes | Limited | Study design not included in USPSTF quality criteria | Highly selected women | No data on adverse events; small number of cases; potential biases with retrospective design
Rebbeck, 2002^73^ | Retrospective cohort with matched comparison group | Yes | Yes | No | Yes | Yes | Yes | Limited | Study design not included in USPSTF quality criteria | Highly selected women | No data on adverse events; small number of cases; potential biases with retrospective design
Kauff et al, 2002^74^ | Prospective cohort | Yes | Yes | No | Yes | Yes | Yes | Limited | Fair | Highly selected women | Small number of cases; short follow-up

USPSTF, U.S. Preventive Services Task Force.