# Appendix Q. Evidence Table of Prophylactic Surgery Studies

*[underlined: Criteria for enrollment in the high-risk category (must meet at least one of these criteria)]
Two or more first-degree relatives with breast cancer
One first-degree relative and two or more second or third-degree relatives with breast cancer
One first-degree relative with breast cancer before the age of 45 years and one other relative with breast cancer
One first-degree relative with breast cancer and one or more relatives with ovarian cancer
Two second or third-degree relatives with breast cancer and one or more with ovarian cancer
One second or third-degree relative with breast cancer and two or more with ovarian cancer
Three or more second or third-degree relatives with breast cancer
One first-degree relative with bilateral breast cancer
[underlined: Criteria for enrollment in the moderate-risk category]
Women with a relative with breast cancer who do not meet above criteria