# Appendix P. Quality Ratings of Chemoprevention Trials

Author, year | Adequate randomization? | Blinding? | Maintenance of comparable groups? | Loss to follow-up? | Measures equal, reliable, valid? | Clear definition of interventions? | Important outcomes considered? | Intention-to-treat analysis? | Quality rating for internal validity | Quality rating for external validity | Limitations
IBIS, 2002^59^ | Yes | Yes | More stopped tamoxifen than placebo due to side effects | 77% loss in tamoxifen and 73% loss in placebo group at 60 months | Yes | Yes | Yes | Yes | Fair to good | Good for similar higher risk women | Loss to follow-up
Fisher et al, 1998^60^ | Yes | Yes | Yes; loss to follow-up similar | 33% loss at >48 months; 63% loss at >60 months | Yes | Yes | Yes | Yes | Fair to good | Good for similar higher risk women | Loss to follow-up
Powles et al, 1998^61^ | Yes | Yes | More stopped tamoxifen than placebo due to side effects | 42% loss at 70 months | Yes | Yes | Yes | Yes | Fair to good | Good for similar higher risk women | Loss to follow-up
Veronesi et al, 1998^62^ | Not provided | Yes | Not provided | 96% loss at 60 months | Yes | Yes | Yes | Yes | Fair | Fair; women in study have hysterectomy | High loss to follow-up; not assessed for breast cancer risk
Cummings et al, 1999^64^ | Yes | Yes | More stopped raloxifene than placebo due to side effects | 22% of raloxifene, 25% of placebo with loss to follow-up at 36 months | Yes | Yes | Yes | Yes | Good | Fair; women in study have osteoporosis | Subjects selected for osteoporosis risk, not breast cancer risk