# Appendix N. Quality Ratings of Studies of Adverse Effects of Risk Assessment and Testing Studies

Author, year | Study design | Random assignment? | Allocation concealed? | Groups similar at baseline? | Eligibility criteria specified? | Blinding: outcome assessors, care provider, patient? | Clear definition of measures? | Intention-to-treat analysis? | Adjustment for potential confounders? | Maintenance of comparable groups? | Important outcomes considered? | Reporting of attrition, contamination, etc.? | Differential loss to follow-up or overall high loss to follow-up? | Quality rating | External validity
Bish et al, 2002a^155^ | Case series | No | N/A | N/A | Yes | N/A | Yes | N/A | No | N/A | Yes | Yes | No | Fair | Family cancer clinic, London
Bish et al, 2002b^164^ | Prospective cohort | No | N/A | Insufficient data to determine | Broad criteria specified | N/A | Yes | No | No | Yes | Yes | Yes | Yes | Poor | Family cancer clinic, London
Brain et al, 2002^156^ | RCT | Yes | Concealed in baseline questionnaire and in clinic appointment letter | Yes | Yes | Implied: individual randomization to trial or control clinic by computer-generated sequence | Yes | Yes | Yes | Yes | Yes | Yes | No | Good | Cancer clinics, Wales
Friedman et al, 1999^157^ | Prospective cohort | No | N/A | Demographic differences reflect those typical of the different risk groups | Yes | N/A | Yes | N/A | No | Yes | Yes | Yes | High loss to follow-up No data on decliners | Fair | Highly educated Jewish persons in Houston, TX, community-based genetic testing program
Fry et al, 2003^165^ | Group RCT | Yes | Not reported | No | Yes | Not reported | Some measures not standard One not clearly defined | No | No | No | Yes | Participation bias present | High loss to follow-up | Poor | Women in SE Scotland referred to clinical genetics dept. for breast cancer genetic risk counseling
Gilbert et al, 1998^166^ | Time series | Yes | N/A | N/A | Yes | N/A | Yes | N/A | No | Not able to determine | Yes | Yes | Difficult to determine—data not given for + vs - family history | Poor | Women in NE Scotland in 3 health centers
Hopwood et al, 1998^158^ | Non-comparative | No | N/A | N/A | Yes | N/A | Yes | N/A | Yes | N/A | Yes | Yes | No | Good/ Fair | Women in Manchester, England, family genetics clinic
Lerman et al, 1998^159^ | Prospective cohort | No | N/A | N/A | Yes | N/A | Yes | N/A | Adjustment for most potential confounders | Yes | Yes | Yes | 30% of test decliners lost to follow-up | Fair | US hereditary breast/ovarian cancer registry composed of highly educated Caucasians
Lobb et al, 2004^160^ | Longitudinal | No | N/A | Yes | Yes | N/A | Yes | N/A | Yes | Yes | Yes | Yes | 19% loss to follow-up | Good | Women in any of 10 familial cancer clinics in four Australian states
Lodder et al, 2002^167^ | Prospective cohort | No | N/A | N/A | Yes | N/A | Yes | N/A | Incomplete | Not able to determine | Incomplete consideration | Yes | High loss to follow-up | Poor | Highly selected European women
Lodder et al, 2001^168^ | Case-Control | No | N/A | Yes | Yes | N/A | Yes | N/A | Adjustment for some potential confounders | Yes | Yes | Yes | High loss to follow-up | Poor | Women who applied for BRCA testing at University Hospital, Rotterdam, and their partners
Meiser et al, 2002^161^ | Prospective cohort | No | N/A | Yes (analysis) | Yes | N/A | Yes | N/A | Potential confounders evaluated and were not significant | Yes | Yes | Yes | Overall follow-up 80%, by group 73% to 87% | Good | Women at 21 cancer clinics in Australia; more highly educated than general population
Meiser et al, 2001^169^ | Before-After | No | N/A | N/A | Yes | N/A | Yes | N/A | No | N/A | Yes | Yes | High loss to follow-up | Poor | Women at 21 cancer clinics in Australia; more highly educated than general population
Ritvo et al, 2000^170^ | Prospective cohort | No | N/A | Incomplete information | General criteria for Cohort A; none for Cohort B | N/A | Not all were clearly defined | N/A | No | Incomplete information | No | Yes | Overall follow-up 77%; Cohort B follow-up 71%; drop-outs younger & less optimistic | Poor | Women at Toronto family cancer clinic seeking genetic risk assessment
Smith et al, 1999^162^ | Prospective cohort | No | N/A | Yes | Yes | N/A | Yes | Participation analysis | Yes | Difficult to assess due to attrition | Yes | Yes | High loss to follow-up | Fair | Members of kindred 2082, most of whom are Mormons
Warner et al, 2003^171^ | Before-After | No | N/A | Yes | Yes | N/A | No | Participation analysis | No | Yes | No | Yes | High loss to follow-up | Poor | Women patients with family history of breast cancer recruited by their doctors who are mambers of Canada's CFPC
Watson et al, 1999^163^ | Before-After | No | N/A | Of 4 clinic sites, 1 had younger & 1 had higher risk women | Yes | N/A | Yes | N/A | Yes | Yes | Yes | Very low attrition | Low loss to follow-up Differential loss data not reported | Good | Women with a family history of breast cancer attending South London genetic clinic

CFPC, College of Family Physicians of Canada; RCT, randomized controlled trial.