# Appendix M. Evidence Table of Studies of Adverse Effects of Risk Assessment and Testing

Author, year | Sub-category | Purpose | Study type | N | Country | Population / Setting | Inclusion / Exclusion criteria | Family history / Risk level definition | Interventions | Results | Conclusions / Recommendations
Bish et al, 2002a^155^ | Psychological/ Behavioral | To study the effect of inconclusive results of the BRAC1/2 genes. | Case series | 71 | England | Women undergoing mutation search testing at Guy's Hospital, London | [underlined: Inclusion:] women with breast or ovarian cancer who had at least a 10% chance of a BRCA1/2 mutation | Mutation risk level: at least 10% chance of BRCA1/2 mutation | Women undergoing BRCA1/2 testing completed questionnaires 2 weeks after blood draws and at 1 week and 6 months after having received a preliminary “inconclusive” result (indicating that 2/3 of the BRCA1 gene had been tested and no mutation had been found). | [underlined: Overall:] 63 of the 71 women approached to participate in the study chose to do so. Two of these were subsequently found to be carrying a mutation and were excluded from the study. Full data analysis was on 61/71 subjects (86%). | Giving inconclusive results for BRCA1/2 testing may be unlikely to cause significant distress.
| | | | | | | | | | [underlined: Distress levels:] During the study period there were no changes in levels of general anxiety (F=0.56)or depression (F=0.38) as measured by HADS. There were no changes in general psychological distress measured by the GHQ-28 (F=0.98). There were no significant changes in level of worry about breast or ovarian cancer (F=2.59 and 0.26).
| | | | | | | | | | [underlined: Perception of risk:] Perceptions of risk of developing breast cancer decreased during the study, with a significant effect between pre-result and immediately afterward (p<0.05). There were no significant changes in screening and surgery intentions.
Bish et al, 2002b^164^ | Psychological/ Behavioral | To examine psychological distress before and after genetic cancer counseling with follow-up for women at differing levels of risk: those who have had breast or ovarian cancer, and those who have not, but have low, medium, and high levels of risk | Longitudinal comparative survey study | 577 | England | Recruited into Department of Clinical Genetics at Guy's Hospital between May 1997 and May 1999 | [underlined: Inclusion:]; 1 women already treated for breast or ovarian cancer; 2 “affected” and “unaffected” women, classified by risk of developing cancer | 4 groups in study: Low risk of developing cancer (< 1 in 6 chance of developing breast or ovarian cancer); Moderate risk (between 1 in 4–6 chance of developing breast or ovarian cancer); High risk (>1 in 3 chance of developing breast or ovarian cancer); Previously had cancer. | Subjects completed a family history sheet detailing the number of cases of cancer in their family, type of cancer, relationship of person to the woman, and age at diagnosis and death. | [underlined: Missing data]: Women with incomplete data were younger than those with complete data (t(418)=2.93, p<0.01), less likely to have a partner (x2=19.7, p<0.001) or to have children (x2=3.9, p<0.05). A higher proportion of affected women had incomplete data (x2=4.6, p<0.05). | No evidence found that genetic counseling raises worry, in fact, worry about developing breast cancer was reduced following genetic counseling across risk levels. The greatest reduction in worry occurred immediately following genetic counseling, implying a positive effect of counseling. Because this reduction in worry lasted through the 12-month follow-up, this demonstrates long-term positive effectiveness of genetic counseling.
| | | | | | | | | Then they met with a doctor or genetic counselor and completed a more detailed family history using the CASH model to provide a risk estimate (between 45 minutes and 1.5 hours). | [underlined: Description of sample: psychological distress and worry]: Significantly less worry about ovarian cancer than breast cancer pre-consultation (t=15.1(188), p<0.0001). This difference persisted at 2 weeks (t=12.8(188), p<0.0001), 6 months (t=12.1(188), p<0.0001), and 12 months (t=10.0(188), p<0.0001). | Worry was much greater about developing breast cancer than ovarian cancer.
| | | | | | | | | Basis of genetic inheritance, the implication of genetic testing, and options for screening and surveillance were explained. | [underlined: Comparison between affected and unaffected women: psychological distress]: Greatest reduction in worry occurred between pre-consultation and short term follow-up (t(186)=7.18, p<0.0001) with a smaller reduction from the 2-week to the 6-month follow-up (t(186)=2.59, p<0.01). This was sustained until the 12-month follow-up with no significant further decrease (t(186)=0.82, ns). A post-hoc test showed that affected women were significantly more worried than women at moderate and high risk about developing ovarian cancer (p<0.05). The greatest reduction in perceived likelihood of carrying for perceived likelihood of carrying a genetic mutation for low risk (F=8.62, p<0.001), moderate risk (F=4.96, p<0.01), high risk (F=4.25, p<0.01), and affected women (F=4.13, p<0.01). Perception of likelihood of carrying a gene mutation was reduced for high risk women following the counseling session (t(36)=2.95, p<0.01), then significantly increased at 6 months post-consultation (t(36)=-2.71, p<0.01), and significantly decreased again at 12 months postconsultation (t(36)=1.87, p<0.05). For affected women, there was a significant reduction in perceived likelihood of carrying a gene mutation at 6 months post-consultation (t(40)=3.42, p<0.01), followed by a significant increase in perceptions at 12 months post-consultation (t(40)=-2.48), p<0.05). For low and moderate risk women, other than a significant reduction following counseling for low risk women, perceptions remain stable (t(23)=2.81, p<0.01). | The consultation greatly reduced perception of likelihood of carrying the mutation. Groups cannot be separated out for this because there was a significant interaction between time and group for this variable. At 6 months, affected women's perception of likelihood significantly decreased (probably because they received an “inconclusive” result right after the consultation, meaning more testing had to be conducted).
| | | | | | | | | 4 total questionnaires: pre-consultation, 2 weeks, 6 months, and 12 months post-consultation. | | Affected women need the same level of counseling as unaffected women and have as many issues and concerns as unaffected women.
| | | | | | | | | | | Actual risk level and perceived risk level were similar and therefore perceptions were realistic.
Brain et al, 2002^156^ | Psychological/ Behavioral | To compare the psychological impact of a multidisciplinary specialist genetics service with surgical provision in women at high risk and lower risk of familial breast cancer | RCT | 1,000 | Wales | Welsh women with family history of breast cancer referred to breast cancer clinic by doctor in 18 month trial period (1996-1997). Randomized to trial (n=366) or control group (n=369). | [underlined: Exclusion:]; 1 history of breast cancer; 2 prior genetic counseling; 3 not a resident of Wales | [underlined: Family history risk definition:] 1st degree female relative diagnosed with breast cancer before age 50; 1st degree female relative with bilateral breast cancer at any age; 2 or more 1st degree relatives with breast cancer; or a 1st and 2nd degree relative with breast cancer. | [underlined: Control Group:] 1) Breast cancer surveillance, 2) surgical assessment of breast cancer risk, 3) option of entering UK Tamoxifen Prevention Trial, and 4) annual follow-up with surveillance and advice | [underlined: Overall:] 1,000 persons referred to the trial. 260 not randomized, total of 740 randomized. Control group: 50 lost to follow-up, 2 risk category missing; a total of 315 completed the trial. Trial group: 5 did not receive intervention as allocated, 28 lost to follow-up; a total of 338 completed the trial. | Specialists other than geneticists might provide assessment of breast cancer risk, reassuring those at reduced risk and targeting high risk women for specialist genetic counseling and testing services.
| | | | | | | | [underlined: Risk definition:] In trial group, risk was assessed on detailed pedigree data collected and analyzed by geneticist using Claus model (Claus et al 1991^105^). | [underlined: Trial Group:] 1, 3, and 4 above AND consultation with a multidisciplinary team with specialist genetic risk assessment and counseling provided by a clinical geneticist and genetic nurse specialist. | [underlined: State anxiety:] Significant main effect of time, with decreased anxiety from baseline to follow-up (p=0.03). | [underlined: Low risk women:] Anxiety and cancer concerns were reduced with personal risk information. High levels of satisfaction, whether or not information based on detailed genetic analysis.
| | | | | | | | In control group, surgical assessment of risk was based on info collected on age, reproductive history, and minimal family history. | | [underlined: Breast cancer worry:] Significant overall reduction from baseline to follow-up. Significant interaction between risk information and time. Decline in women at low risk (t(106)=5.92,p<0.001) and moderate risk (t(443)=12.13, p<0.001), but not at high risk. | [underlined: High risk women:] Risk information, even unfavorable, does not appear to create significant anxiety. Concerns about breast cancer risk remained and they were less satisfied with consultation in either group. Implication: breast cancer worry may impact quality of life for women who recognize they are at high risk.
| | | | | | | | | | [underlined: Satisfaction:] Significantly lower in high risk group (p<0.001).
| | | | | | | | | | [underlined: Perception of risk:] Marginally significant trend to increased perceived risk in high risk women in the trial group.
| | | | | | | | | | [underlined: Interest in genetic testing:] Effect of risk information not significant.
Friedman et al, 1999^157^ | Psychological/ Behavioral | To understand the psychological impact of receiving negative BRCA1 mutation test results in Ashkenazim | Prospective cohort | 333 | USA | Baylor College of Medicine, Houston, TX | [underlined: Inclusion:]; 1 age 21 or older; 2 at least 50% Ashkenazi Jewish ancestry; 3 ability to speak-read-write English; 4 ability to provide informed consent | [underlined: Average risk:] tested negative and had negative family and personal histories of breast and ovarian cancer. Risk of developing breast or ovarian cancer was that of the general population. | 2-hour educational session including information about frequency of breast and ovarian cancer in general population and in Ashkenazi Jewish population, discovery of the 185delAG mutation, associated risk of breast, ovarian, and colon cancer in women and colon and prostate cancer in men. Also focused on goals of the study, eligibility criteria, possible outcomes of testing and implications for surveillance, recommended screening guidelines in general population, and current surveillance and prevention guidelines for those at increased risk for breast or ovarian cancer. Subjects informed of potential risk of insurance discrimination based on test results. | [underlined: Overall:] 333 attended the educational session, 309 consented to study. 289 tested for 185delAG mutation. 6 tested positive and were excluded from the study. Of the 283 remaining, 199 provided complete data on measures used in the study. | After controlling for gender and age, increased risk subjects reported slightly but significantly higher levels of cancer-specific distress than average risk subjects at the 6-month follow-up. For all subjects, general psychological distress declined during this 6 month period. Cancer-specific distress had declined among all subjects at the 1-month follow-up. While the average risk group's cancer-specific distress level continued to decline 6 months after receiving test results, the increased risk group's distress level had begun a climb back to baseline. Data suggest that women and younger people may need more counseling during genetic testing.
| | | | | | | | [underlined: Increased risk:] tested negative but had positive family or personal histories of breast or ovarian cancer and either had no information about their affected relatives' genetic status or had affected relatives with negative DNA test results. | Personal history of cancer obtained by subjects indicating whether they had ever been diagnosed with breast, ovarian, colon, prostate, or other cancer and age of diagnosis. | [underlined: IES scores:] Decreases in cancer-specific distress had occurred in both groups (increased risk and average risk) at the 1-month follow-up. At 6-month follow-up, level of distress in the average risk group had decreased even more, whereas that in the increased risk group had begun a return to baseline. Gender significantly related to IES (p<0.01), with women having higher scores. Age was related negatively to IES (p<0.05), with younger people scoring higher.
| | | | | | | | Positive family history defined as one 1st or two 2nd degree relatives with breast cancer (age <50 yrs.) or ovarian cancer. | Follow-up questionnaires at 1 and 6 months after notification of test results, then yearly follow-up for 5 years. | [underlined: Differences between groups:] Increased risk and average risk groups differed significantly on the demographic measures (gender and age) entered in the first block (p=0.003). Addition of POMS-SF and IES baseline measures in second block did not result in significant change (p=0.26); nor was the addition of the same measures at the 1-month follow-up (third block) (p=0.34). Addition of the distress measures at the 6-month follow-up (fourth block) also was not associated with significant change (p=0.07). With demographic and psychological distress measures at baseline, 1 month, and 6 months, difference between the two groups was statistically significant (p=0.006). Standardized regression coefficients for gender (-1.80), age (0.03), and the IES (0.09) differed significantly from zero (p<0.05). Although the overall model was significant, difference between groups was based primarily upon differences in IES scores, age, and gender at 6- month follow-up (p=0.02, p=0.03, and p=0.02, respectively).
Fry et al, 2003^165^ | Psychological/ Behavioral | Compare the psychological impact of two models of breast cancer genetic services | Cluster RCT | 574 | Scotland | From 3/98–11/99, any woman referred from general practice for breast cancer genetic risk counseling. | [underlined: Inclusion:]; 1 resident of region; 2 complete baseline questionnaire | Risk of Breast Cancer: Genetics consultant and nurse specialist assigned categorical risk assessment based on Cancer Research Campaign (1977) criteria as follows: Risk of breast cancer is moderately increased if one of the following is present: a) 1st degree relative with a history of breast cancer; b) two 1st or 2nd degree relatives on the same side of the family with breast cancer before age 60 or with ovarian cancer; c) three 1st or 2nd degree relatives on the same side of the family with breast or ovarian cancer; d) 1st degree relative with breast cancer in both breasts; e) 1st degree male relative with breast cancer. | [underlined: Standard (regional) service]: Subjects completed a family history form and baseline questionnaire. Those assessed as low risk and their physicians were sent a letter to explain this. Those assessed as moderate or high risk or for whom an adequate risk assessment could not be made were offered an appointment at the familial breast cancer clinic. Clinic consultation involved detailed discussion with genetics consultant and specialist breast surgeon on options for risk management. Clinical breast exam and mammography (where appropriate) were included. After the appointment, subjects' physicians were sent a summary letter. Subjects were asked to participate in a follow-up. | [underlined: Overall]: Of the 574 women invited to participate in the study, 201 were excluded, 23 refused to participate, 123 did not respond, 31 did not return baseline questionnaire (11 for administrative reasons, 13 for protocol violation). 131/185 subjects assigned to the standard service completed the trial (71%); 113/188 assigned to the novel service completed the trial (60%). | These two models of cancer genetics services evaluated were generally comparable in terms of subjects' psychological outcomes. The proportion of women with “case-level” distress decreased by up to 4 weeks and cancer worry continued to decrease up to 6 months. Unlike in previous studies, reductions in cancer worry were not dependent on objective risk. Decisions regarding implementation of the novel community-based service should be based on the resources required and client satisfaction with the service.
| | | | | | 170 general practices (84% of those invited to participate) were randomized to refer subjects to:; 1 standard (regional) service (131/185 subjects completed the trial) or; 2 novel (community-based) service (113/188 subjects completed the trial). | [underlined: Exclusion:]; 1 symptomatic; 2 diagnosed with breast or ovarian cancer; 3 previous consultation with a different clinic about family history of cancer | If necessary, further information or confirmation of relatives' diagnoses was obtained by a genealogist and from the Scottish Cancer Registry. | [underlined: Novel (community-based) service]: Subjects were sent to an appointment at a community-based clinic run by a genetics nurse specialist who ascertained family history of cancer and compiled a family tree to determine risk assessment. Subjects were informed of risk level by letter. Those at low risk were offered information and reassurance and were discharged from the clinic. They and their physicians were sent a summary letter. Those at moderate or high risk were offered an appointment at the regional center with a geneticist and a genetics nurse specialist. Subjects were asked to take part in a follow-up. | [underlined: Cancer worry]: For all subjects, there was a significant reduction in scores on the BCWS during the study. Post-hoc analysis revealed the greatest reduction in scores occurred between baseline and 4 weeks (p<0.0000) with a smaller significant reduction between 4 weeks and 6 months (p=0.003).
| | | | | | | | | | [underlined: Distress level]: There was a significant decrease in the overall proportion of subjects experiencing “case level ” (general psychological) distress over the study period (p=0.003), although the reduction was only significant between baseline and 4 weeks (p=0.0004).There were no significant differences in the proportion of subjects with “case-level” distress between trial arms or risk groups at 3 different assessment points.
Gilbert et al, 1998^166^ | Psychological/ Behavioral | Psychological impact of false-positive mammography and effects of recall on women with and without a family history of breast cancer | Pre-test/Post-test observational | 2,357 | Scotland | 3 health centers in Scotland that were participating in the UKBSP were selected. | [underlined: Inclusion:]; 1 women; 2 50–64 years of age; 3 patient of 1 of 3 health centers in Scotland participating in the UKBSP | Familial Risk: Self-reported to radiographer who evaluated risk based on criteria set by the local Department of Medical Genetics. Subjects likely to be at least twice the population risk of breast cancer were considered positive for family history. | Mailed HADS completed before screening. At screening appointment completed HADS (most prior to mammography, a few after mammography). If they were recalled for further testing they completed another HADS and were given two additional HADS to be completed at 5 weeks and 4 months by mail. Health Questionnaire (HQ) completed at screening and recall. Increased risk subjects were informed of this and offered referral for detailed assessment and counseling. If this confirmed increased risk status, they were offered screening every 18 months instead of every 3 years. | [underlined: Overall]: Of the 2,357 sent the first HADS, 2,110 (90%) were returned. 1,463 (70%) completed the HADS at screening. 133 were recalled due to increased risk of BC, but 9 were excluded due to cancer diagnosis. 90 subjects completed all HADS. 1,561 ( 66%) subjects completed the HQ at screening and 105 completed all HQs. | Women were more likely to have significant anxiety at recall visits than screening, but the anxiety was transient and significantly lowered after 5 weeks. Contrary to the hypothesis, women with a family history were less likely to be significantly depressed at screening. This implies that screening may be reassuring to these women. Recalling women with family history to assessment clinics only causes increased anxiety. Sending them their results with the option to attend genetic clinics could help alleviate this anxiety.
| | | | | | | [underlined: Exclusion]: positive for cancer | | | [underlined: On HADS anxiety]: Subjects were more anxious at baseline than at the 4-month follow-up (t=2.70, p=0.008), at recall than at screening (t=2.75, p=0.007), and at screening than at the 4-month follow-up (t=2.59, p=0.01). Subjects were less anxious at the 5-week follow-up than at recall (t=3.08, p=0.003), and at the 4-month follow-up than at recall (t=4.13, p<0.0005).
| | | | | | | | | | [underlined: On HADS depression]: Subjects were more depressed at baseline than at screening (t=2.04, p=0.04), and at recall than at screening (t=2.25, p=0.03).
| | | | | | | | | | [underlined: Clinical significance]: Subjects were more likely to have borderline or clinically significant anxiety at recall than baseline (p<0.05), screening (p<0.001), 5-week follow-up (p<0.005) or 4-month follow-up (p<0.02). Overall distress levels returned to normal within 5 weeks.
| | | | | | | | | | [underlined: Effects of positive family history]: Subjects with a family history of breast cancer were more anxious than those without at the 4-month follow-up (F=4.14, p=0.045). Subjects with a family history of breast cancer were less likely to have borderline or clinically significant depression than those without a family history of breast cancer (X2=5.76, p<0.02). Subjects with a family history of breast cancer were less likely to have stress-related changes on the HQ at screening than those without a family history of breast cancer (F=6.38, p=0.01). Subjects without a family history of breast cancer were more anxious at baseline than at the 4-month follow-up (F=4.57, p=0.05). There was no significant difference between the two groups in proportions of subjects with borderline or significant anxiety.
| | | | | | | | | | [underlined: Subjects with incomplete data]: Subjects who did not return the 5-week follow-up HADS were more depressed at screening and baseline (t=2.46, p=0.02 and t=2.61, p=0.01 respectively). Ss who did not return the 4-month follow-up HADS were more depressed at screening and baseline (t=2.26, p=0.03 and t=1.96, p=0.05 respectively).
Hopwood et al, 1998^158^ | Psychological/ Behavioral | To understand psychological support needs for women at high genetic risk for breast cancer | Cohort | 176 | England | All were consecutive first-time attendees at the Family History Clinics (Manchester, UK). | [underlined: Inclusion:]; 1 women aged 18–45,; 2 living within a 25-mile radius of the FHC | Risk was at least twofold greater than the population for breast cancer (i.e., 1:6 lifetime risk or greater as assessed using the Claus model). | Women were interviewed 3 months after genetic risk counseling because of a family history of breast cancer.; 1 Postal questionnaire prior to counseling.; 2 At attendance for risk counseling, women were asked to complete GHQ together with several other self-report measures.; 3 Questionnaires completed again at 3, 6, 9, and 12 months later.; 4 Home visit conducted at 3 months to carry out research interviews, which included administration of the Psychiatric Assessment Schedule. | [underlined: Overall:] Of 176 women approached, 174 agreed to participate in the study, but 7 declined the interview, 7 were lost to follow-up, and 2 were subsequently found to be ineligible. | Prevalence rate for psychological distress when measured by a self-report questionnaire was double that ascertained by psychiatric interview, which is regarded as the gold standard. Other studies using self-report measures should interpret data with this in mind.
| | | | | | | | | | [underlined: GHQ scores:] Compliance at baseline was 85% (n=34), and 94% at 3 months (n=148). Prevalence of psychological distress, with a cut-off score >5, was 30.6% at baseline and 26.4% at 3 months. An examination of the 4 subscales of GHQ showed that 9.7% scored≥5 on the somatic scale, 14.2% on the anxiety subscale and 3% each on the depression and suicidal ideation subscales at baseline. At 3 months, proportions were 12.2%, 14.9%, 6.8%, and 3.4%, respectively. When analysis was restricted to 105 women with evaluable assessments on all occasions, prevalence was 30.5% and 24.8% respectively. Baseline scores compared with pre-counseling risk estimates showed no significant difference (p=0.087). Significant difference between psychological distress and perceived risk post-counseling (p=0.0053). Women with accurate risk knowledge post-counseling had significantly lower scores than those who underestimated (p=0.0034) or who overestimated (p=0.0447). | Interview data suggests that psychiatric morbidity was not apparently caused by the genetic counseling. This suggests that routine genetic risk consultations do not facilitate disclosure of distress or unresolved grief, and the use of a screening instrument together with a second-stage assessment interview should be explored further.
| | | | | | | | | | [underlined: Psychiatric Assessment Schedule:] Psychiatric disorder was confirmed in 21 (13.3%) of the study participants at 3 months. Most women had multiple concerns, but none reported risk counseling as a precipitant for their distress.
| | | | | | | | | | [underlined: Estimation of risk:] Previous to risk counseling, 10% accurately estimated risk of breast cancer, while 50% accurately estimated after (p=0.0000). More women continued to overestimate (17%) than underestimate (11%). In general, giving women an accurate estimate of their probability of breast cancer when they perceived it to be much lower did not appear to trigger clinical anxiety or depression.
Lerman et al, 1998^159^ | Psychological/ Behavioral | To identify members of hereditary breast and ovarian cancer families who are at risk for adverse psychological effects of genetic testing | Prospective cohort | 396 | USA | Men and women who were members of 33 extended hereditary breast or ovarian cancer families in a hereditary cancer registry (27 BRCA1-linked and 6 BRCA2 linked). Study enrollment: 7/94–2/97. | [underlined: Inclusion:]; 1 18 or over; 2 unaffected at-risk family members (without cancer) and those with cancer | Not reported | Structured baseline phone interview. Family information session on BRCA testing, 1–2 hours duration, with semi-structured protocol including field trips. Option of phone education session instead. All were given option of receiving BRCA1/2 test results. Those who received results participated in an individual counseling session with an oncologist, including information on personal cancer risk for self and offspring, and available options for surveillance and prevention. At 1 and 6 months post-disclosure, all subjects were re-contacted by phone to assess psychological distress. | [underlined: Overall:] 396 individuals completed a baseline interview. Retention rate was significantly higher for women (86%) than men (76%) (p=0.008), and for mutation carriers and non-carriers (91%) compared with those who declined to receive results (p=0.001). Of the 327 subjects, 109 were non-carriers, 97 were mutation carriers and 121 declined to receive test results. | In BRCA1/2-linked families, persons with high levels of cancer-related stress who decline genetic testing may be at risk for depression. They may benefit from education and counseling and should be monitored for possible adverse effects.
| | | | | | | [underlined: Exclusion:] people with psychiatric or cognitive disorders | | | [underlined: Distress levels:] Presence of cancer-related stress symptoms at baseline was strongly predictive of the onset of depressive symptoms in family members who were offered but declined testing. At follow-up evaluation, 8% of noncarriers, 14% of carriers, and 19% of decliners were depressed (p=0.02). At the 1-month follow-up interview, there was a significant association between study group and depression in the high-stress subgroup (p=0.001). At 1 month, depression rates increased from 26% to 47% in subjects with high levels of baseline distress who declined test results, while rates in non-carriers decreased from 41% to 11% (p=0.0004). There was no change in depression rates in mutation carriers (20% to 23%). These significant differences were evident at the 6-month follow-up (p=0.04).
Lobb et al, 2004^160^ | Psychological/ Behavioral | To examine the effect of different consultant communication styles on a variety of outcomes | Longitudinal | 193 | Australia | Women from high-risk breast cancer families attending their first consultation before genetic testing | [underlined: Inclusion:]; 1 18 or over; 2 able to give written consent; 3 fluent in English; 4 no prior testing for or carrier of BRCA1 or BRCA2 | Not reported | Self-administered questionnaires were mailed when the appointment was made and 4 weeks after their genetic consultation. Questionnaires included Breast Cancer Genetics Knowledge, Expectations, Perceived Risk, IES, HADS, and Satisfaction with Genetic Counseling Scale. Women came to the center for their genetic consultation. The consultation was recorded, analyzed, and coded to capture 10 aspects of genetic counseling. Not all counselors incorporated all aspects and this was the basis for the study. | [underlined: Anxiety:] Women who had more aspects of genetic testing discussed had a decrease in anxiety after 4 weeks (p=0.03). Women receiving a letter summarizing their consultation had lower anxiety (p=0.012) and a trend toward less anxiety about breast cancer (p=0.089). Women who received four or more supportive communications were more anxious about breast cancer (p=0.000). | Women who understand what is being presented to them have decreased depression. This can imply that women may feel overwhelmed with the amount of information they receive and may feel worse if they are not helped to understand it. Providing a written summary of the consultation helped with accurate risk perception.
| | | | | | | | | | [underlined: Depression:] Women whose consultants facilitated understanding more had a decrease in depression (p=0.052).
| | | | | | | | | | [underlined: Risk Accuracy:] Women receiving a letter summarizing their consultation had increased risk accuracy (p=0.023).
Lodder et al, 2001^168^ | Psychological/ Behavioral | To identify individuals at risk for high distress in the weeks following disclosure of BRCA 1/2 mutation test result | Pre-test/Post-test observational | 118 | Netherlands | University Hospital, Rotterdam; subjects part of an evaluation of distress in healthy women who apply for genetic testing with their partners | [underlined: Inclusion:]; 1 healthy women with a 25% or 50% risk of being a BRCA1/2 carrier; 2 applied for BRCA1 genetic testing at the University of Rotterdam between 12/95–4/98.; 3 subjects asked their partners to participate | Genetic risk: subjects have a 25% or 50% risk of being a BRCA1/2 carrier. | Pre-test assessment prior to blood sampling, with subjects taking home questionnaires to complete. Pre-test interview usually scheduled in the weeks following blood sampling, but 14% occurred just after the genetic counseling session. After disclosure of test result, psychologist met with subjects and their partners to discuss feelings. Post-test assessment (questionnaires and interviews) occurred 1 –3 weeks later. 58% of interviews occurred in subjects' homes, 35% in the hospital clinic, and 7% by phone, all according to subject's preference. | [underlined: Overall]: 118 women and their partners were asked to participate; 21% decided not to and 9% dropped out, leaving 78/118 (66%) and 56 partners. | BRCA mutation carriers who are anxious at pre-test would likely benefit from assessment for psychological support, as would non-mutation carriers with a sister who received a positive BRCA test result.
| | | | | | | | | | [underlined: Distress levels]: The course of anxiety and depression from pre-test to post-test was significantly different for BRCA and non- BRCA subjects (p<0.05). Non- BRCA subjects became less anxious and depressed from pre- to post-test, and BRCA subjects showed a slight increase in anxiety and depression. Level of post-test anxiety, depression, and cancer-related distress was strongly related to the level of pre-test distress on the same scales (p varies from 0.0001 to 0.05). Non- BRCA subjects who recently had a sister identified with BRCA had higher post-test levels of depression than other non- BRCA subjects and BRCA subjects (p=0.01). Partners of BRCA subjects reported higher distress levels at post-test than non- BRCA partners, and 1/3 had borderline to high anxiety levels at post-test. Level of cancer-related distress in partners of BRCA subjects was low.
Lodder et al, 2002^167^ | Psychological/ Behavioral | To understand the emotional impact of genetic testing outcome and decisions on risk management | Pre-test/Post-test observational | 118 | Netherlands | 118 women who underwent genetic testing at the University Hospital, Rotterdam between 12/95–04/98 were asked to participate with their partners. | [underlined: Inclusion:]; 1 50% risk of carrying BRCA1/BRCA2 mutation; 2 healthy; 3 women | 50% risk of being a BRCA1/2 mutation carrier. | Subjects came in for genetic counseling and testing. If found to have a mutation in BRCA1/2 they were referred to the Family Cancer Clinic of the Daniel den Hoed Cancer Center/University Hospital, Rotterdam to discuss the implications. Subjects then decided on their plan of action (either prophylactic mastectomy or surveillance). Subjects were asked to participate in the psychological study at testing time. Right after meeting with genetic counseling the subjects met with a psychologist and were given the questionnaires to complete. Directly after test disclosure subjects met with the psychologist again. There were follow-ups at 1–3 weeks and 6 and 12 months after test disclosure. Subjects were split into 3 groups: 1) undergoing prophylactic mastectomy (average age 35, n=14), 2) undergoing surveillance (average age 42, n=12), and 3) non-mutation carriers (average age 37, n=37). | [underlined: Overall:] Of the 118 asked to participate, 93 signed the informed consent (78%). 11 dropped out prior to the second assessment and 3 dropped out during the follow-up phase, leaving 79, but 16 were excluded because they only had 25% risk. 63 were left (26 mutation carriers and 37 non-mutation carriers) (53% response rate). 12 did not complete all questionnaires. | The majority of women undergoing prophylactic mastectomy were between 30–40 years of age and had young children. Only one women was between 30–40 years of age, and one had young children in the surveillance group. Women undergoing prophylactic mastectomy had higher levels of distress over the study period, many of whom had made the decision pre-test. The low anxiety in the surveillance group might be linked to their trust of the surveillance process. Women in the prophylactic mastectomy group were less satisfied with their body image/sexuality pre-test. The majority of women in the prophylactic mastectomy group did not regret their decision, but this could be related to “cognitive dissonance.”
| | | | | | | [underlined: Exclusion:] 25% risk of carrying BRCA1/BRCA2 mutation | | | [underlined: Distress:] Mutation carriers undergoing prophylactic mastectomy had higher anxiety at all points than the other two groups (p<0.05). Mutation carriers undergoing surveillance had lower anxiety than the other two groups, except at post-test. Non-mutation carriers were similar to mutation carriers undergoing surveillance on their level of distress for post-test and follow-up. Non-mutation carriers were more distressed and anxious pre-test than post-test and follow-up. There were more mutation carriers undergoing prophylactic mastectomy with borderline to high anxiety (29%) at 1-year follow-up than for the surveillance group (8%) or the non-mutation carriers (16%). 3 subjects who opted for prophylactic mastectomy and 2 non-mutation carriers requested psychological support within 12 months following the results, no one in the surveillance group did. Anxiety prior to the results was higher than the normal female population for those who later underwent prophylactic mastectomy or non-mutation carriers. Subjects who opted for surveillance had anxiety levels similar to those of the normal female population prior to the results. All levels of anxiety were similar to or lower than the normal female population at 12-month follow-up.
| | | | | | | | | | [underlined: Body Image:] Only 11 of those who opted for prophylactic mastectomy, 8 who opted for surveillance, and 18 non-mutation carriers completed these questionnaires, due to deciding not to and administrative issues. 8 partners of subjects who opted for prophylactic mastectomy and 13 partners of subjects in either the surveillance group or non-mutation carriers completed their questionnaires. Subjects in the prophylactic mastectomy group were similar to the surveillance group on importance of their physical appearance and their sexual relationship at pre-test (p=0.17 and p=0.6, respectively). At pre-test subjects in the prophylactic mastectomy group reported more problems than the other groups. The prophylactic mastectomy group reported more body image/sexuality problems post-test. Non-mutation carriers' body image/sexuality increased at post-test.
Meiser et al, 2001^169^ | Psychological/ Behavioral | To evaluate the impact of genetic counseling in women at risk of developing hereditary breast cancer | Comparative | 276 | Australia | 14 familial cancer clinics and 6 outreach clinics in 5 Australian states (New South Wales, Victoria, South Australia, Queensland, and Western Australia). Clinics provide comprehensive service including risk assessment, genetic testing, and advice on early detection and prophylactic strategies. | [underlined: Inclusion]: unaffected women with a family history of breast cancer | Clinic staff were asked to make a judgment on whether a subject's family history was either consistent or not consistent with a dominantly inherited predisposition to breast cancer. Subjects were then classified as being at high risk or moderately increased risk. | Baseline questionnaires 12-month follow-up questionnaires | [underlined: Overall]: Of 276 eligible women, 30 declined or did not return baseline questionnaire (89% response rate). Of these, 218 returned the 12-month follow-up questionnaire (79% response rate), comprising the final sample. | Breast cancer genetics knowledge was significantly improved 12-months post-counseling. Greater increases in knowledge were associated with higher education levels.
| | | | | | | [underlined: Exclusion:]; 1 prior diagnosis of breast or ovarian cancer; 2 unable to give informed consent; 3 limited literacy in English; 4 received a genetic test result prior to attending for genetic counseling or during the follow-up period | [underlined: Moderately increased risk]: lifetime risk of 1 in 4 to 1 in 8. | | [underlined: Breast cancer knowledge]: Scores of breast cancer knowledge increased significantly from baseline to follow-up (p<0.0001). Breast cancer genetics knowledge at baseline (p<0.0001) and educational level (p=0.025) were significantly associated with breast cancer genetics knowledge at follow-up. No other variables were significantly correlated. | Statistically significant decrease in breast cancer anxiety 12-months post-counseling. Improvements in perceived risk were associated with decreases in breast cancer anxiety at the 12-month follow-up, suggesting that the anxiety-reducing effects of genetic counseling may be the result of more accurate risk perceptions.
| | | | | | | | [underlined: High risk]: lifetime risk of 1 in 2 to 1 in 4. Pedigrees and relative's medical records were confirmed to support risk level judgment. | | [underlined: Perception of risk]: No overall association between educational level and changes in magnitude of perceived risk from baseline to follow-up (p=0.347). Overall proportion of women whose risk perception accuracy improved, compared with those whose perception deteriorated, was not significant (p=0.36). A logistic regression predicting improvement in accuracy of perceived risk at 12-month follow-up showed that neither age (p=0.55), objective risk (p=0.99), marital status (p=0.53), nor educational level (p=0.17) were significantly associated. | It is unknown what mechanisms account for the association between improvements in perceived risk and reductions in breast cancer anxiety. It is plausible that women feel reassured by lower than expected risk estimates leading to decrease in breast cancer anxiety.
| | | | | | | | Expert opinions of clinical geneticists were used as a gold standard to estimate breast cancer risk in high-risk women (since no universally accepted standards exist). | | [underlined: Anxiety levels]: At baseline, BDI mean = 6.2, STAI-state mean = 35.8, IES mean = 15.1. At 12-month follow-up, BDI mean = 7.4, STAI-state mean = 37.3, IES mean = 13.8. Inspection of means did not suggest differences from baseline to 12-month follow-up for BDI and STAI-state. There was a statistically significant decrease in breast cancer anxiety from baseline to follow-up (p=0.037), which was significantly associated with improvements in perceived risk (p=0.008). None of the other sociodemographic and family history variables were associated with changes in breast cancer anxiety at follow-up. | Future studies should explore whether providers of genetic counseling present information on advantages and disadvantages of screening strategies in different ways, depending on a woman's educational level. Content of genetic counseling should be reviewed to ensure women receive and take away the right message.
Meiser et al, 2002^161^ | Psychological/ Behavioral | To study the psychological adjustment of women who have undergone testing for BRCA 1/2 breast and ovarian cancer susceptibility | Prospective cohort | 143 | Australia | Between 11/96 and 10/00, women in outreach clinics (30 BRCA carriers, 60 non-carriers) who had BRCA1/2 testing and 53 women not tested (control group). Subjects were healthy with a family history of breast or ovarian cancer who approached 1 of 14 familial cancer clinics (FCC) and 6 associated clinics. | [underlined: Inclusion:]; 1 no history of breast or ovarian cancer; 2 eligible for genetic testing; 3 at risk for developing hereditary breast cancer with an affected living relative to provide blood sample | Used for estimate of risk, pre-genetic testing. | Comprehensive service provided to all including risk assessment, genetic testing, and advice regarding cancer surveillance and prophylactic strategies. | [underlined: Overall]: 89% of eligible subjects returned baseline questionnaire; overall follow-up rate was 80%. | Those without deleterious BRCA mutations derive psychological benefits from genetic testing. Those who test positive for deleterious BRCA mutations may anticipate a sustained increase in breast cancer distress following disclosure, although no other adverse effects were found in this group
| | | | | | | [underlined: Exclusion:]; 1 limited English literacy; 2 being tested for founder mutations only | 25% mutation ( BRCA1/2) carrier risk: Subjects from high risk family with closest affected relative or relative with a BRCA mutation is 2nd degree. | Subjects invited to participate via pre-clinic phone call before face-to-face genetic counseling. | [underlined: Comparison]: Compared with controls, BRCA subjects had significantly higher breast cancer distress post-notification: 7–10 days (p=0.005) and 12 months (p=0.045). Trend: higher breast cancer distress 4 months post-notification (p=0.054). Compared with controls, BRCA subjects showed significant decrease in state anxiety 12 months post-notification (p=0.0007), and BRCA negative subjects showed a significant decrease in state anxiety 7–10 days post-notification (p=0.024). BRCA-negative subjects showed a trend of lower state anxiety than controls at 4 months post-notification (p=0.066). BRCA-negative subjects had a decrease in depression at 4 months post-notification (p=0.024) compared with controls.
| | | | | | | | 50% risk: Subjects from high risk family who has either a 1st degree affected relative or unaffected relative with a known pathogenic BRCA1/2 mutation. | Questionnaires and consent forms were mailed and subjects returned them prior to their appointment.
| | | | | | | | | Follow-up questionnaires were mailed at 7–10 days, 4 months, and 12 months post-disclosure for subjects receiving test results. Each time a subject received a test result, an analogous mail-out of follow-up questionnaires was triggered to a recently recruited control subject when one was available. Subjects not eligible for testing because of no living relative from whom a blood sample could be obtained served as controls. Reminder calls were made as required.
Ritvo et al, 2000^170^ | Psychological/ Behavioral | To report on the psychological responses of women given familialgenetic evaluations for ovarian cancer risk | Pre-test/Post-test observational | 78 | Canada | Between 10/97 and 7/98, women in Toronto, self- or doctor-referred due to suspected genetic ovarian cancer risk to Familial Ovarian Cancer Genetic Clinic (FOCGC). | [underlined: Inclusion]: suspected genetic ovarian cancer risk | [underlined: High risk]: 1) 2 or more 1st degree relatives with breast or ovarian cancer < age 50, 1 of whom had ovarian cancer; or 2 or more affected relatives who are descendants of an ethnic group with known high BRCA mutation, 2) or 4 2nd or 3rd degree relatives diagnosed with breast or ovarian cancer < age 50, 3) or family pedigree consistent with autosomal dominant pattern of inheritance. | Family history questionnaire and baseline psychiatric battery sent to subjects for completion prior to first clinic appointment. Those with eligible family history given appointment for complete family genetic assessment. Standard method used to orient subjects and to obtain information. Initial visit: subject seen by team of genetic counselor, geneticist, and gynecologist oncologist. Family history/pedigree reviewed and subject assigned to low, moderate, or high risk category. Baseline questionnaire. Initial and follow-up appointments: pelvic exam, transvaginal ultrasound, and serum CA-125 screening. All questionnaires completed at home or in clinic with assistance of research assistant as needed. Immediately after clinic assessment, subjects completed brief survey, and a semi-structured phone interview occurred 48–72 hours later. Follow-up assessment by mail 9 and 12 months later. | [underlined: Overall]: 23% drop-out rate between baseline and follow-up. Drop-outs were younger (p=0.07) and scored lower on the optimism test (p<0.02) than subjects. | Assisting people in understanding their risk status and adapting to risk assessment is a fundamental part of the counseling process.
| | | | | | [underlined: Cohort A]: Eligible subjects consisted of 78 women who attended FOCGC for initial appointments and familial genetic risk assessment. | | [underlined: Moderate risk]: 1) At least one 1st degree relative with breast or ovarian cancer before age 50; additional 2nd or 3rd degree relatives meeting the same criteria that increase risk substantially, 2) or one 1st degree relative meeting the same criteria who is a descendant of an ethnic group with known high BRCA mutation incidence. | | [underlined: Depression levels]: Higher self-assessed cancer risk levels (vs. as assessed by professionals) at baseline predicted higher level of depression at follow-up (p<0.03). This was especially visible in the high risk group: 57% of subjects who reported self-assessment of high risk were depressed, while only 15% of subjects categorized by professionals as high risk were depressed. Optimistic expectancy was a significant factor in depression score variance. Subjects who were more optimistic at baseline were less likely to be distressed or depressed at follow-up 9 or 12 months later (p<0.001) Although the study refers to 2 longitudinal cohorts, no statistically significant data are presented on Cohort B.
| | | | | | | | [underlined: Low risk]: 1) a 1st degree relative with ovarian cancer or one with breast cancer before age 50, 2) 2nd or 3rd degree relatives with ovarian cancer and/or breast cancer who do not meet criteria as above for moderate or high risk.
Smith et al, 1999^162^ | Psychological/ Behavioral | To determine the effect of siblings' test results on psychological distress 1–2 weeks after BRCA1 mutation testing | Longitudinal | 500 | USA | Genetic counseling sessions took place at University of Utah. Most kindred members live in Utah and Idaho and are Mormon. | [underlined: Inclusion:] age 18 or older | All subjects are members of Kindred 2082 (K2082), the largest known kindred identified with a BRCA1 mutation. More than 750 living adult members have been identified. Most kindred members live in Utah and Idaho and are Mormon. | Subjects given baseline questionnaire. Subjects who still wished to be tested received extensive pre- and post-test family and genetic counseling with a genetic as well as a marriage and family counselor. After the first session, subjects had blood drawn for DNA analysis. Results were provided at second session, if subjects elected to receive results. | [underlined: Overall:] Of 500 eligible subjects, 82% (n=408) completed the baseline interview, 59% (n=296) also completed first counseling session, and 54% (n=269) had blood drawn for purposes of mutation testing. 91% (269 of 296) who received counseling decided to be tested. Of 269 who completed baseline and had blood drawn, 88% (n=238) received test results in person from a genetic counselor, and 86% (n=230) completed the follow-up interview 1–2 weeks after receiving results. Of these 230, 92% (n=212) were tested, received results, completed the 1–2 week follow-up, and had complete data on all relevant variables. | Studies of high risk families provide an opportunity to preview how genetic testing results may affect individuals within a family context.
| | | | | | | [underlined: Exclusion:]; 1 unable to consent; 2 unable to attend two in-person genetic counseling sessions | | 1–2 weeks later, subjects were contacted for the first follow-up interview. | [underlined: IES scores:]At the 1–2 week interview, there was high level of consistency with Cronbach's α of 0.88 (0.89 for females and 0.84 for males). The Intrusion and Avoidance subscales have a simple Pearson correlation coefficient of 0.64 (p<0.01). | The familial context in which genetic counseling is conducted may be important for understanding how individuals react to their own test results.
| | | | | | | | | Additional questionnaires were administered at various points in time up to 2 years after receiving results (these data are not used in this paper). | [underlined: Interaction Effects Model:] For women, the adverse effect of being a carrier vs a noncarrier on test-related distress was significant. The undesirable effects of testing positive were attenuated when tested siblings were all positive (p<0.10) and when siblings had mixed results (p<0.01). These findings strongly suggest that the largest adverse consequences for carrier women were among those whose tested siblings were noncarriers. | Future investigators should anticipate how psychological consequences and family dynamics may change when genetic testing is conducted in other settings, where individuals do not have access to such counseling services.
| | | | | | | | | | [underlined: Summary:] Largest adverse psychological consequences for female carriers, relative to noncarriers, were for those who were tested first and those whose tested siblings were noncarriers. Results suggest that individuals' immediate reaction to test results varies by the results of their siblings, although this association varies by gender. | This study is the first to report the short-term psychological effects of BRCA1 testing among tested family members.
Warner et al, 2003^171^ | Psychological/ Behavioral | To asses the usefulness of an information aid on women's knowledge, breast cancer related anxiety, risk perception, and attitudes toward screening and to evaluate women's satisfaction with the aid. | Pre-test/Post-test | 203 | Canada | Family practices in Ontario where the physicians are members of the College of Family Physicians of Canada's National Research System. Recruitment took place between February 1999 to May 2000. | [underlined: Inclusion:]; 1 English speaking; 2 female; 3 patient of physician from the College of Family Physicians of Canada's National Research System; 4 older than 18 years; 5 any family history of breast cancer | Low risk | A baseline questionnaire was completed in the doctor's office. Then subjects given an “information aid” consisting of a booklet (at 8th grade reading level) and a 30-minute audiotape that together highlight breast cancer pathogenesis, risk factors, prevention, screening, and presentation; an overview of breast cancer genetics; and criteria to help women identify their risk level themselves. Three case scenarios of women at low, moderate, and high risk of breast cancer are presented in the materials. A second questionnaire was completed at home. A third questionnaire was mailed 4 weeks after the second. | [underlined: Overall]: Of 405 randomly selected physicians, 97 agreed to recruit up to 6 (median=3) subjects. 59 of these physicians enrolled (61%). 203 were recruited, and 160 completed all three questionnaires (79%). 39% low risk, 35% moderate risk, 26% high risk. The information aid was rated excellent or very good by 91% of the women; 96% thought it should be available in family physicians' offices. | The information aid is a useful resource for women and primary care physicians and could facilitate appropriate risk assessment and management of women with a family history of breast cancer.
| | | | | | | | Moderate risk | | [underlined: Satisfaction with information]: There were significant differences in satisfaction with the information aid by hereditary breast cancer risk level. Those at low risk rated increased knowledge of hereditary breast cancer 97%, whereas those at high risk rated knowledge 72% (p<0.001). Those at low risk rated increased understanding of hereditary breast cancer 95%, whereas those at high risk rated increased understanding 81% (p<.034). Those at low risk rated how well it answered questions about hereditary breast cancer 92%, whereas those at high risk rated this 77% (p<.051).
| | | | | | | | High risk (specified, but not defined in article) | | [underlined: Knowledge of breast cancer:] Knowledge of genetics, incidence, and disease prevention and treatment improved significantly overall with 3 out of 11 items (p<0.0001), 2 out of 11 items (p=0.001), and 5 out of 11 items (p=0.027), although baseline knowledge was higher among more educated women (p=0.034).
| | | | | | | | | | [underlined: Breast cancer worry]: Worry about breast cancer did not differ at baseline across the 3 risk groups and was not affected by use of the aid. There was a significant increase from 85% to 96% (p<0.001) in intent to undergo clinical breast examination, particularly in the low and moderate risk groups.
Watson et al, 1999^163^ | Psychological/ Behavioral | To investigate perception of genetic risk and the psychological effects of genetic counseling in women with a family history of breast cancer | Prospective cohort | 303 | England | First-time genetic clinic attendees recruited from four South London genetic counseling centers (Royal Marsden NHS Trust Hospital [two separate clinics], Mayday University Hospital, and St. Georges' Hospital) | [underlined: Inclusion:]; 1 female with family history of breast cancer; 2 never clinically affected by cancer; 3 no known serious mental illness; 4 age 18 or older; 5 able to complete a questionnaire | Breast cancer risk calculated using CASH model based on the number of breast cancer cases in 1st and 2nd degree relatives, age of family members at disease onset, and age of woman presenting for genetic counseling. | Self-administered questionnaires given at genetic clinic immediately, pre- and post-genetic consultation and by postal survey at 1-, 6-, and 12-month follow-ups. | [underlined: Overall:] Of the 303 eligible, 10 were not approached due to clinic time constraints, another 10 declined invitation, and 1 was excluded for missing baseline data, comprising final sample of 282. | Evidence indicates that there are high levels of cancer-related worry that compare unfavorably to previously gathered data on general population risk samples. The finding that genetic counseling fails to alleviate this cancer-specific distress in a substantial minority of women is contrary to previous US findings, reporting a reduction in cancer anxiety several months post-counseling. However, a single counseling session may not be sufficient to shift worries in some women and probably unreasonable to expect otherwise. General levels of psychological morbidity remain unaffected by genetic counseling. Of concern is the substantial minority of women who did not benefit from counseling because they continued to overestimate risk and their worry about developing breast cancer was unrelieved. Also, a small group of women who underestimated risk may have failed to benefit in terms of future management of their health because they continued to underestimate risk following counseling.
| | | | | | | | | | No significant difference on demographic variables from non-participants. | [underlined: Summary:] This study highlights some problems in the provision of cancer genetic counseling. Some women continue to believe they are at high risk despite being told otherwise. Anxiety about breast cancer is not alleviated by genetic counseling, and women who continue to overestimate their risk and worry about breast cancer are likely to go on seeking unnecessary screening if they are not reassured.
| | | | | | | | | | Response rate was 96% (n=272) immediately post-counseling, 88% (n=249) at 1- and 6-month follow-ups, and 93% (n=263) at 12 months.
| | | | | | | | | | [underlined: GHQ:] One-third had notable levels of distress. There was no statistically significant change in general mental health at each follow-up compared with pre-counseling level.
| | | | | | | | | | [underlined: Cancer Anxiety and Helplessness / IES:] No statistically significant changes in levels of cancer-specific distress. Follow-up assessment revealed that 13% (35/268) had received some psychological intervention during the 12 months since attending the clinic. Of these, 7% (n=19) had received psychotropic medication, 4% (n=10) had engaged in psychological counseling, and 2% (n=6) had received both forms of intervention.
| | | | | | | | | | [underlined: Levels of state anxiety:] Anxiety levels at pre-counseling were at similar levels to those reported in healthy women attending for breast cancer screening (mean 38.7), with a significant downward shift immediately post-counseling (mean 35.2, p<0.001).
| | | | | | | | | | [underlined: Perception of risk:] Specific figures about risk, provided within genetic counseling, tend not to be remembered. Continual over-estimators may be worrying unnecessarily and excessively about breast cancer risk and under-estimators appear undisturbed by the information that their risk is greater than they thought. Under-estimators were not significantly different from the rest of the sample in terms of their scores for intrusive and avoidant thoughts about breast cancer risk when assessed pre-counseling. However, at 12 months, their scores were significantly lower than the rest on each of the scales (avoidance p=0.02; intrusion p=0.006), indicating that in the long-term they are less likely to report having intrusive thoughts about breast cancer risk. High levels of cancer-specific distress were found in pre-genetic counseling, with 28% reporting that they worried about breast cancer “frequently or constantly” and 18% that worry about breast cancer as a “severe or definite” problem. Following genetic counseling, levels of cancer-specific distress were unchanged. General mental health remained unchanged over time (33% psychiatric cases were detected pre-genetic counseling, and 27% 12 months after genetic counseling).

BCWS, Breast Cancer Worry Scale; BDI, Beck Depression Inventory; BSI, Brief Symptom Inventory; CES-D, Center for Epidemiologic Studies Depression Scale; GHQ, General Health Questionnaire (12-, 28-, or 30-item); GSI, Global Severity Index; HADS, Hospital Anxiety and Depression Scale; IES, Impact of Events Scale; NSI, non-standardized instrument; POMS-SF, Profile of Mood States short form; RCT, randomized controlled trial; SCL-90, Symptom Checklist--90; STAI, State-Trait Anxiety Inventory; UKBSP, UK Breast Screening Programme.