# Appendix L. Evidence Table of Penetrance Studies

Author, year | Population or risk group | N | Risk to age: | Breast cancer risk BRCA1 (%, 95% CI) | Breast cancer risk BRCA2 (%, 95% CI) | Breast cancer risk BRCA1 or BRCA2 (%, 95% CI) | Breast cancer risk mutation negative (%, 95% CI) | Relative risk breast cancer(95% CI) | General population's risk breast cancer | Ovarian cancer risk BRCA1 (%, 95% CI) | Ovarian cancer risk BRCA2 (%, 95% CI) | Ovarian cancer risk BRCA1 or BRCA2 (%, 95% CI) | Ovarian cancer risk mutation negative (%, 95% CI) | Relative risk ovarian cancer (95% CI) | General population's risk ovarian cancer
Anglian BC Study Group, 2000^27^ | Breast cancer diagnosed < 55 | 8 families of BRCA1 mutations | 40 yrs | 20 (0–50) | 6 (0–17) | 10 (0–21) | | | 0.4 | 3 (0–30) | 1 (0–5) | 1 (0–5) | | | 0.1
| | 16 families of BRCA2 mutations
Anglian BC Study Group, 2000 | Breast cancer diagnosed < 55 | 8 families of BRCA1 mutations | 50 yrs | 32 (2–62) | 18 (2–32) | 21 (5–34) | | | 1.5 | 11 (1–74) | 3 (0–19) | 4 (1–18) | | | 0.3
| | 16 families of BRCA2 mutations
Anglian BC Study Group, 2000 | Breast cancer diagnosed < 55 | 8 families of BRCA1 mutations | 60 yrs | 46 (3–82) | 31 (3–53) | 34 (5–55) | | | 3.1 | 24 (2–96) | 6 (1–39) | 10 (2–37) | | | 0.7
| | 16 families of BRCA2 mutations
Anglian BC Study Group, 2000 | Breast cancer diagnosed < 55 | 8 families of BRCA1 mutations | 70 yrs | 47 (5–82) | 56 (5–80) | 54 (14–76) | | | 5.0 | 36 (4–99) | 10 (1–55) | 16 (4–51) | | | 1.0
| | 16 families of BRCA2 mutations
Anglian BC Study Group, 2000 | Breast cancer diagnosed < 55 | 8 families of BRCA1 mutations | 80 yrs | 48 (7–82) | 74 (7–94) | 69 (11–90) | | | | 47 (5–100) | 14 (2–68) | 22 (6–65)
| | 16 families of BRCA2 mutations
Antoniou et al, 2003^130^ | Meta-analysis of studies that included 1st degree relatives of breast cancer prevalent and incident and/or ovarian cancer prevalent and incident cases positive for a BRCA1 or BRCA2 mutation | 280 families of BRCA1+ | 70 yrs | 65 (51–75) | 45 (33–54) | | | | | 39 (22–51) | 11 (4.1–18)
| | 218 families of BRCA2+
Antoniou et al, 2003 | Above, case with early-onset breast cancer (<35) | * families of BRCA1+ | 70 yrs | 87 (67–95) | 55 (16–76) | | | | | 51 (9.1–73) | 35 (0.61*)
| | 46 families of BRCA2+ | | | | | | | | | *typo in paper
| | *not stated
Antoniou et al, 2003 | Above, case with older-onset breast cancer ([underlined: >]35) | * families of BRCA1+ | 70 yrs | 61 (41–74) | 49 (32–61) | | | | | 32 (11–49) | 3 (0–7)
| | 102 families of BRCA2+
| | *not stated
Antoniou et al, 2003 | Above, case with ovarian cancer | 117 families of BRCA1+ | 70 yrs | 56
| | 50 families of BRCA2+
Antoniou et al, 2002^28^ | Breast cancer diagnosed < 55 Multiple case families, ads and referrals | 21 BRCA1+ | 30–39 | 12.9 | 8.3 | | 0.4 | | | 0.4 | 0.3 | | 0.1
| | 18 BRCA2+
Antoniou et al, 2002 | Breast cancer diagnosed < 55 Multiple case families, ads and referrals | 21 BRCA1+ | 40–49 | 26.2 | 20.7 | | 1.5 | | | 11.4 | 0.8 | | 0.2
| | 18 BRCA2+
Antoniou et al, 2002 | Breast cancer diagnosed < 55 Multiple case families, ads and referrals | 21 BRCA1+ | 50–59 | 32.1 | 35.3 | | 3.0 | | | 18.3 | 5.2 | | 0.6
| | 18 BRCA2+
Antoniou et al, 2002 | Breast cancer diagnosed < 55 Multiple case families, ads and referrals | 21 BRCA1+ | 60–69 | 35.3 | 50.3 | | 4.9 | | | 25.9 | 9.1 | | 1.0
| | 18 BRCA2+
Brose et al, 2002^21^ | Seek breast cancer counseling, documented BRCA1 mutation | 147 BRCA1 | 70 | 78.3 (74.1–82.4) | | | | | 12.9 | 49.9 (44.9–55.0) | | | | | 1.7
Ford et al, 1998^131^ | 4 or more cases of female breast cancer diagnosed < 60 or male breast cancer diagnosed at any age | 64 BRCA1+ | 30 | 3.6 (0–14) | 0.6 (0–19)
| | 32 BRCA2+
Ford et al, 1998 | 4 or more cases of female breast cancer diagnosed < 60 or male breast cancer diagnosed at any age | 64 BRCA1+ | 40 | 18 (0–35) | 12 (0–24)
| | 32 BRCA2+
Ford et al, 1998 | 4 or more cases of female breast cancer diagnosed < 60 or male breast cancer diagnosed at any age | 64 BRCA1+ | 50 | 49 (28–64) | 28 (9–44) | | | | | | 0.4 (0–1)
| | 32 BRCA2 +
Ford et al, 1998 | 4 or more cases of female breast cancer diagnosed < 60 or male breast cancer diagnosed at any age | 64 BRCA1+ | 60 | 64 (43–77) | 18 (22–65)
| | 32 BRCA2+
Ford et al, 1998 | 4 or more cases of female breast cancer diagnosed < 60 or male breast cancer diagnosed at any age | 64 BRCA1+ | 70 | 71 (53–82) | 84 (43–95) | | | | | | 27 (0–47)
| | 32 BRCA2+
Hopper et al, 1999^132^ | Population-based, breast cancer diagnosed < 40 | 9 BRCA1+ | 40 | | | 8 (0–20)
| | 9 BRCA2+
Hopper et al, 1999 | Population-based, breast cancer diagnosed < 40 | 9 BRCA1+ | 50 | | | 10 (0–24)
| | 9 BRCA2+
Hopper et al, 1999 | Population-based, breast cancer diagnosed < 40 | 9 BRCA1+ | 60 | | | 31 (7–56)
| | 9 BRCA2+
Hopper et al, 1999 | Population-based, breast cancer diagnosed < 40 | 9 BRCA1+ | 70 | | | 40 (16–64)
| | 9 BRCA2+
King et al, 2003^134^ | New York cancer centers, breast cancer, Ashkenazi Jewish | 67 BRCA1+ | 30 | 3 (1) | 0 | 2 (1) (SD) | | | | 0 | 0
| | 37 BRCA2+
King et al, 2003 | New York cancer centers, breast cancer, Ashkenazi Jewish | 67 BRCA1+ | 40 | 21 (3) | 17 (5) | 20 (3) | | | | 3 (1) | 2 (2)
| | 37 BRCA2+
King et al, 2003 | New York cancer centers, breast cancer, Ashkenazi Jewish | 67 BRCA1+ | 50 | 39 (4) | 34 (7) | 37 (4) | | | | 21 (4) | 2 (2)
| | 37 BRCA2+
King et al, 2003 | New York cancer centers, breast cancer, Ashkenazi Jewish | 67 BRCA1+ | 60 | 58 (5) | 48 (8) | 55 (4) | | | | 40 (5) | 6 (5)
| | 37 BRCA2+
King et al, 2003 | New York cancer centers, breast cancer, Ashkenazi Jewish | 67 BRCA1+ | 70 | 69 (5) | 74 (8) | 71 (4) | | | | 46 (6) | 12 (7)
| | 37 BRCA2+
King et al, 2003 | New York cancer centers, breast cancer, Ashkenazi Jewish | 67 BRCA1+ | 80 | 81 (6) | 85 (8) | 82 (5) | | | | 54 (7) | 23 (12)
| | 37 BRCA2+
Liede et al, 2002^129^ | Healthy Jewish women with a family history of breast or ovarian cancer | 27 BRCA1 185delAG | 10-yr risk for carriers; less follow-up for non-carriers | | | 21 | < 1 | 18 (2.1–157) | | | | 28 | < 1 | 32 (4.0–260)
| | 4 BRCA1 5382insC
| | 2 BRCA2 6174delT
Moslehi et al, 2000^135^ | Hospital-based ovarian cancer, Ashkenazi Jewish | 43 BRCA1 185delAG | 55 | 31.3 | 6.1
| | 14 BRCA1 5382insC
| | 29 BRCA2 6174delT
Moslehi et al, 2000 | Hospital-based ovarian cancer, Ashkenazi Jewish | 43 BRCA1 185delAG | 65 | 45.9
| | 14 BRCA1 5382insC
| | 29 BRCA2 6174delT
Moslehi et al, 2000 | Hospital-based ovarian cancer, Ashkenazi Jewish | 43 BRCA1 185delAG | 75 | 43.8 | 36.8 | | | | | | 26.6
| | 14 BRCA1 5382insC
| | 29 BRCA2 6174delT
Moslehi et al, 2000 | Hospital-based ovarian cancer, Ashkenazi Jewish | 43 BRCA1 185delAG | 75 | 44.2 | | | | | | 10.1
Moslehi et al, 2000 | Hospital-based ovarian cancer, Ashkenazi Jewish | 14 BRCA1 5382insC | 75 | 39.3 | | | | | | 21.0
Risch et al, 2001^133^ | Population-based, ovarian cancer | 39 BRCA1+ | 80 | 68 | | | 9.9 | | | 36 | | | 2.5
| | 21 BRCA2+
Satagopan et al, 2001^137^ | Case series, breast cancer, Ashkenazi Jewish | 57 BRCA1+ | 20–29 | 0.6 (0.3–1.5) | 0.1 (0–0.5)
| | 23 BRCA2+
Satagopan et al, 2001 | Case series, breast cancer, Ashkenazi Jewish | 57 BRCA1+ | 30–39 | 7 (4–16) | 1.4 (0.5–5.4)
| | 23 BRCA2+
Satagopan et al, 2001 | Case series, breast cancer, Ashkenazi Jewish | 57 BRCA1+ | 40–49 | 18 (12–34) | 6 (2–14)
| | 23 BRCA2+
Satagopan et al, 2001 | Case series, breast cancer, Ashkenazi Jewish | 57 BRCA1+ | 50–59 | 31 (22–56) | 15 (8–28)
| | 23 BRCA2+
Satagopan et al, 2001 | Case series, breast cancer, Ashkenazi Jewish | 57 BRCA1+ | 60–69 | 46 (31–80) | 26 (14–50)
| | 23 BRCA2+
Satagopan et al, 2001 | Case series, breast cancer, Ashkenazi Jewish | 57 BRCA1+ | 70–79 | 59 (40–93) | 38 (20–68)
| | 23 BRCA2+
Satagopan et al, 2001 | Case series, breast cancer, Ashkenazi Jewish | 57 BRCA1+ | 80–89 | 70 (47–98) | 47 (26–80)
| | 23 BRCA2+
Satagopan et al, 2002^136^ | Hospital-based ovarian cancer, Ashkenazi Jewish | 103 BRCA1+ | 20–29 | | | | | | | 1 (0–2) | 0.2 (0–1)
| | 44 BRCA2+
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 103 BRCA1+ | 30–39 | | | | | | | 3 (1–7) | 0.7 (0–3)
| | 44 BRCA2+
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 103 BRCA1+ | 40–49 | | | | | | | 11 (7–21) | 3 (1–8)
| | 44 BRCA2+
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 103 BRCA1+ | 50–59 | | | | | | | 23 (16–44) | 11 (7–21)
| | 44 BRCA2+
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 103 BRCA1+ | 60–69 | | | | | | | 37 (25–71) | 21 (13–41)
| | 44 BRCA2+
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 103 BRCA1+ | 70–79 | | | | | | | 52 (35–90) | 32 (20–60)
| | 44 BRCA2+
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 103 BRCA1+ | 80+ | | | | | | | 63 (44–96) | 42 (26–73)
| | 44 BRCA2+
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 76 BRCA1 185delAG | 20–29 | | | | | | | 1 (0.4–3)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 76 BRCA1 185delAG | 30–39 | | | | | | | 3 (1–8)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 76 BRCA1 185delAG | 40–49 | | | | | | | 12 (7–25)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 76 BRCA1 185delAG | 50–59 | | | | | | | 39 (23–100)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 76 BRCA1 185delAG | 60–69 | | | | | | | 66 (37–100)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 76 BRCA1 185delAG | 70–79 | | | | | | | 85 (53–100)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 76 BRCA1 185delAG | 80+ | | | | | | | 93 (63–100)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 27 BRCA1 5382insC | 20–29 | | | | | | | 1 (0–5)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 27 BRCA1 5382insC | 30–39 | | | | | | | 3 (0–14)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 27 BRCA1 5382insC | 40–49 | | | | | | | 17 (6–55)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 27 BRCA1 5382insC | 50–59 | | | | | | | 22 (11–60)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 27 BRCA1 5382insC | 60–69 | | | | | | | 29 (16–69)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 27 BRCA1 5382insC | 70–79 | | | | | | | 37 (22–78)
Satagopan et al, 2002 | Hospital-based ovarian cancer, Ashkenazi Jewish | 27 BRCA1 5382insC | 80+ | | | | | | | 44 (29–86)
Struewing et al, 1997^11^ | Ad recruitment, Jewish | 120 BRCA1 or BRCA2 | 50 | | | 33 (23–44) | 4.5 (4.0–5.0) | | | | | 7 (2–14) | 0.4 (0.2–0.6)
Struewing et al, 1997 | Ad recruitment, Jewish | 120 BRCA1 or BRCA2 | 70 | | | 56 (40–73) | 13 (12–14) | | | | | 16 (6–28) | 1.6 (1.2–2.0)
Struewing et al, 1997 | Ad recruitment, Jewish | 41 BRCA1 185delAG | 70 | | | | | | | 12
Struewing et al, 1997 | Ad recruitment, Jewish | 20 BRCA1 5382insC | 70 | | | | | | | 22
Struewing et al, 1997 | Ad recruitment, Jewish | 59 BRCA2 6174delT | 70 | | | | | | | | 18
Warner et al, 1999^138^ | Breast cancer, prevalent cases Ashkenazi Jewish | 34 BRCA1+ | 70 | 59.9 | 28.3
| | 15 BRCA2+