# Appendix K. Evidence Table of Studies of Prevalence of Mutation Among Controls Without Breast or Ovarian Cancer

Author, year | Population | AJ | Risk for mutation* | N tested | N BRCA1 positive | N BRCA2 positive | N BRCA1 or BRCA2 positive | BRCA1 mutation frequency | BRCA2 mutation frequency | BRCA1 or BRCA2 mutation frequency
Fodor et al, 1998^125^ | Referral for prenatal carrier testing (NY) | Y | FH-NS | 1,715 | 20 | 18 | 38 | 1.2% | 1.0% | 2.2%
| AJ
Frank et al, 2002^33^ | Clinical consecutive samples (US) | N | Hgh | 1,706 | | | 148 | | | 8.7%
| Non-AJ, no cancer, non-FH
Frank et al, 2002 | Clinical consecutive samples (US) | Y | Hgh | 1,176 | | | 196 | | | 16.7%
| AJ, no cancer, non-FH
Hartge et al, 1999^86^ | Population-based (US) | Y | FH-NS | 3,419 | | | 59 | | | 1.7%
| AJ
Hartge et al, 1999 | Population-based (US) | Y | Hgh | 783 | | | 30 | | | 3.8%
| AJ, age: < 40 yrs
Hartge et al, 1999 | Population-based (US) | Y | Mod | 2,636 | | | 32 | | | 1.2%
| AJ, age: < 40 yrs
Hartge et al, 1999 | Population-based (US) | Y | FH-NS | 690 | | | 19 | | | 2.8%
| AJ, age: < 40 yrs
Hartge et al, 1999 | Population-based (US) | Y | Hgh | 137 | | | 10 | | | 7.3%
| AJ, age: < 40 yrs, FH
Hartge et al, 1999 | Population-based (US) | Y | Mod | 553 | | | 9 | | | 1.6%
| AJ, age: < 40 yrs, non-FH
Hartge et al, 1999 | Population-based (US) | Y | FH-NS | 1,112 | | | 23 | | | 2.1%
| AJ, age: 40–49 yrs
Hartge et al, 1999 | Population-based (US) | Y | Hgh | 249 | | | 12 | | | 4.8%
| AJ, age: 40–49 yrs, FH
Hartge et al, 1999 | Population-based (US) | Y | Mod | 863 | | | 11 | | | 1.3%
| AJ, age: 40–49 yrs, non-FH
Hartge et al, 1999 | Population-based (US) | Y | FH-NS | 811 | | | 14 | | | 1.7%
| AJ, age: 50–59 yrs
Hartge et al, 1999 | Population-based (US) | Y | Hgh | 192 | | | 6 | | | 3.1%
| AJ, age: 50–59 yrs, FH
Hartge et al, 1999 | Population-based (US) | Y | Mod | 619 | | | 8 | | | 1.3%
| AJ, age: 50–59 yrs, non-FH
Hartge et al, 1999 | Population-based (US) | Y | FH-NS | 806 | | | 6 | | | 0.7%
| AJ, age: > 60 yrs
Hartge et al, 1999 | Population-based (US) | Y | Hgh | 205 | | | 2 | | | 1.0%
| AJ, age: > 60 yrs, FH
Hartge et al, 1999 | Population-based (US) | Y | Mod | 601 | | | 4 | | | 0.7%
| AJ, age: > 60 yrs, non-FH
Liede et al, 2002^129^ | Healthy Jewish women with a FH of breast or ovarian cancer; exclude incident breast and ovarian cancer (US) | Y | Hgh | 213 | 31 | 2 | 33 | 14.6% | 0.9% | 15.5%
Liede et al, 2002 | Healthy Jewish women with a FH of breast or ovarian cancer; exclude incident breast and ovarian cancer (US) | Y | Hgh | 199 | 19 | 2 | 21 | 9.5% | 1.0% | 10.6%
Malone et al, 2000^143^ | Population-based (US) | N | Mod | 71 | 0 | 0 | | 0.0% | 0.0%
| Age: < 45 yrs, FH: 1st-degree of ≥ 4 breast cancers
Modan et al, 2001^127^ | Population-based (Israel) | Y | FH-NS | 751 | 3 | 10 | 13 | 0.4% | 1.3% | 1.7%
| AJ
Oddoux et al, 1996^128^ | Population-based (US) | Y | FH-NS | 848 | | 8 | | | 0.9%
| AJ, NYU Medical Center
Oddoux et al, 1996 | Population-based (US) | Y | FH-NS | 407 | | 4 | | | 0.9%
| AJ, NIH
Roa et al, 1996^12^ | Population-based | Y | FH-NS | 3,116 | 38 | 47 | 85 | 1.2% | 1.5% | 2.7%
| AJ
Satagopan et al, 2001^137^ | Population-based (US) | Y | FH-NS | 3,434 | 32 | 30 | 62 | 0.9% | 0.9% | 1.8%
| AJ
Satagopan et al, 2001 | Population-based (US) | Y | FH-NS | 692 | 11 | 8 | 19 | 1.6% | 1.2% | 2.7%
| AJ, age: < 40 yrs
Satagopan et al, 2001 | Population-based (US) | Y | FH-NS | 1,113 | 12 | 11 | 23 | 1.1% | 1.0% | 2.1%
| AJ, age: 40–49 yrs
Satagopan et al, 2001 | Population-based (US) | Y | FH-NS | 1,629 | 9 | 11 | 20 | 0.6% | 0.7% | 1.2%
| AJ, age: > 50 yrs
Struewing et al, 1995^126^ | Unselected for breast cancer or AJ, FH | Y | FH-NS | 858 | 8 | | | 0.9%
Struewing et al, 1997^11^ | Population-based (US) | Y | FH-NS | 3,440 | 32 | 30 | 62 | 0.9% | 0.9% | 1.8%
| AJ, age: > 20 yrs
Struewing et al, 1997 | Population-based (US) | Y | Mod | 2,648 | 11 | 21 | 32 | 0.4% | 0.8% | 1.2%
| AJ, non-FH
Struewing et al, 1997 | Population-based (US) | Y | Hgh | 786 | 21 | 9 | 30 | 2.7% | 1.1% | 3.8%
| AJ, FH

AJ, Ashkenazi Jewish; FH, family history; FH-NS - family history non-selected; NIH, National Institutes of Health.

* Average risk, no first-degree relatives with breast or ovarian cancer; moderate risk (Mod), one first-degree relative with cancer or AJ without a first-degree relative with cancer; high risk (Hgh), two or more first-degree relatives with cancer or AJ with one or more first-degree relatives with breast or ovarian cancer.