# Appendix A. Search Strategies

## MEDLINE®—1966 to October 1, 2004

### Ethical, Legal and Social Implications of Genetic Screening

1 exp Breast Neoplasms/ or exp ovarian neoplasms
2 exp Mass Screening/ or gene.mp. or genes.mp. or genetic$.mp. or BRCA$.mp.
3 exp LEGISLATION
4 exp JURISPRUDENCE
5 lj.fs.
6 3 or 4 or 5
7 exp bioethical issues/ or exp bioethics/ or ethic$.mp. or bioethic$.mp.
8 exp human rights
9 6 or 7 or 8
10 1 and 2 and 9
11 limit 10 to (human and English language)

### Genetic Screening

1 exp Preventive Medicine
2 exp Family Practice
3 exp Primary Health Care
4 exp Physicians, Family
5 1 or 2 or 3 or 4
6 exp Breast Neoplasms/ or exp ovarian cancer
7 exp Genetic Predisposition to Disease
8 exp Genetic Screening
9 6 and (7 or 8)
10 exp Breast Neoplasms/ge or exp ovarian cancer/ge [Genetics]
11 9 or 10
12 5 and 11

### Genetic Counseling

1 exp Genetic Counseling/ or Genetic counseling.mp. or genetic counselling.mp.
2 decision making.mp. or exp Decision Making
3 exp RISK
4 risk$.mp.
5 exp Breast Neoplasms/ or breast neoplasm$.mp. or Breast cancer$.mp. or exp ovarian neoplasms/ or ovarian cancer$.mp. or ovarian neoplasm$.mp.
6 1 and (2 or 3 or 4) and 5

### Prediction of Disease Occurrence

1 exp Breast Neoplasms/mo, pc, ep, eh or exp ovarian neoplasms/mo, pc, ep, eh [Mortality, Prevention & Control, Epidemiology, Ethnology]
2 exp GENES, BRCA1/ or exp BRCA1 PROTEIN/ or BRCA1.mp.
3 exp GENES, BRCA2/ or exp BRCA2 PROTEIN/ or BRCA2.mp.
4 2 or 3
5 exp Breast Neoplasms/ge or exp ovarian neoplasms/ge [Genetics]
6 (sensitivity and specificity).mp. [mp=title, abstract, cas registry/ec number word, mesh subject heading]
7 exp “Sensitivity and Specificity”
8 risk$.mp. or exp RISK
9 5 and (6 or 7 or 8)
10 1 and 4 and 9

### Prediction Models

1 (gail adj model$).mp. [mp=title, abstract, name of substance, mesh subject heading]
2 (claus adj model$).mp. [mp=title, abstract, name of substance, mesh subject heading]
3 1 or 2
4 exp Models, Statistical
5 exp risk
6 exp Breast Neoplasms/ge [Genetics]
7 4 and 5 and 6
8 3 or 7
9 limit 8 to human
10 limit 9 to English language
11 limit 9 to abstracts
12 10 or 11

### BRCA Studies

1 exp case-control studies
2 brca$.mp.
3 1 and 2
4 exp Breast Neoplasms
5 exp Ovarian Neoplasms
6 4 or 5
7 3 and 6

### Harms of Risk Assessment and Testing

1 exp Breast Neoplasms/ or exp ovarian neoplasms
2 exp genetic screening/ae or exp genetic services/ae or exp genetic counseling/ae or exp genetic screening/px or exp genetic services/px or genetic counseling/px
3 exp Breast Neoplasms/ge or exp ovarian neoplasms/ge [Genetics]
4 psychological stress.mp. or exp Stress, Psychological
5 (1 and 2) or (3 and 4)

### Interventions: General

1 exp Breast Neoplasms/nu, pc, dh, rt, dt, rh, su, th, tr or exp ovarian neoplasms/nu, pc, dh, rt, dt, rh, su, th, tr
2 exp Treatment Outcome/ or treatment outcome$.mp.
3 exp “Outcome Assessment (Health Care)”/ or outcome assessment$.mp.
4 1 or 2 or 3
5 exp Breast Neoplasms/mo, ep, eh or exp ovarian neoplasms/mo, ep, eh
6 exp Breast Neoplasms/ or exp ovarian neoplasms
7 exp MORTALITY/ or mortal$.mp. or mortality.fs.
8 exp INCIDENCE/ or incidence$.mp. or epidemiology.fs. or ethnology.fs.
9 7 or 8
10 6 and 9
11 5 or 10
12 exp RISK
13 risk$.mp.
14 exp Genetic Predisposition to Disease/ or genetic predisposition to disease$.mp.
15 pedigree.mp. or exp PEDIGREE
16 12 or 13 or 14 or 15
17 exp Breast Neoplasms/ge or exp ovarian neoplasms/ge
18 exp GENES, BRCA1/ or exp BRCA1 PROTEIN/ or BRCA1.mp.
19 exp GENES, BRCA2/ or exp BRCA2 PROTEIN/ or BRCA2.mp.
20 17 or 18 or 19
21 4 and 11 and 16 and 20

### Interventions: Surgery

1 exp Breast Neoplasms/pc [Prevention & Control]
2 exp Ovarian Neoplasms/pc [Prevention & Control]
3 (mastectom$ or oophoectom$ or ovariectom$).mp. [mp=title, abstract, name of substance, mesh subject heading]
4 1 or 2
5 3 and 4
6 (family adj5 histor$).mp. [mp=title, abstract, name of substance, mesh subject heading]
7 exp Genetic Predisposition to Disease
8 brca.mp.
9 (BRCA1 or BRCA2).mp. [mp=title, abstract, name of substance, mesh subject heading]
10 6 or 7 or 8 or 9
11 5 and 10
12 limit 11 to human
13 limit 12 to English language
14 limit 12 to abstracts
15 13 or 14

### Interventions: SERMs and Oral Contraceptives

1 exp Breast Neoplasms/pc [Prevention & Control]
2 exp Ovarian Neoplasms/pc [Prevention & Control]
3 1 or 2
4 (family adj5 histor$).mp. [mp=title, abstract, name of substance, mesh subject heading]
5 exp Genetic Predisposition to Disease
6 brca.mp.
7 (BRCA1 or BRCA2).mp. [mp=title, abstract, name of substance, mesh subject heading]
8 4 or 5 or 6 or 7
9 exp Selective Estrogen Receptor Modulators
10 (serm or serms or tamoxifen or raloxifene).mp. [mp=title, abstract, name of substance, mesh subject heading]
11 9 or 10
12 3 and 8 and 11
13 exp Contraceptives, Oral
14 3 and 8 and 13
15 12 or 14
16 limit 15 to human
17 limit 16 to English language
18 limit 16 to abstracts
19 17 or 18

### Harms of Interventions

1 exp Breast Neoplasms/dt, su or exp ovarian neoplasms/dt, su
2 exp Breast Neoplasms/pc or exp ovarian neoplasms/pc
3 chemoprevention.mp. or exp CHEMOPREVENTION
4 primary prevention.mp. or exp Primary Prevention
5 2 or 3 or 4
6 postoperative complications.mp. or exp Postoperative Complications
7 intraoperative complications.mp. or exp Intraoperative Complications
8 ae.xs. or ct.fs.
9 psychological stress.mp. or exp Stress, Psychological
10 6 or 7 or 8 or 9
11 1 and 5 and 10