# Appendixes

Appendix A. Search Strategies

Appendix B. Inclusion/Exclusion Criteria By Key Question

Appendix C. U.S. Preventive Services Task Force (USPSTF) Quality Rating Criteria

Appendix D. Statistical Methods

Appendix F. Reviewers

Appendix G. Evidence Table of Genetic Counseling Studies

Appendix H. Quality Ratings of Genetic Counseling Studies

Appendix I. Evidence Table of Studies of Prevalence and Penetrance

Appendix J. Evidence Table of Studies of Prevalence of Mutation Among Breast or Ovarian Cancer Cases

Appendix K. Evidence Table of Studies of Prevalence of Mutation Among Controls Without Breast or Ovarian Cancer

Appendix L. Evidence Table of Penetrance Studies

Appendix M. Evidence Table of Studies of Adverse Effects of Risk Assessment and Testing

Appendix N. Quality Ratings of Studies of Adverse Effects of Risk Assessment and Testing Studies

Appendix O. Evidence Table of Chemoprevention Trials

Appendix P. Quality Ratings of Chemoprevention Trials

Appendix Q. Evidence Table of Prophylactic Surgery Studies

Appendix R. Quality Ratings of Prophylactic Surgery Studies

Appendix S. Sensitivity Analyses