# References

1 Ogden CL, Carroll MD, Flegal KM. Epidemiologic trends in overweight and obesity. Endocrinology & Metabolism Clinics of North America 2003; 32(4):741–760, vii.
2 Troiano RP, Flegal KM, Kuczmarski RJ, Campbell SM, Johnson CL. Overweight prevalence and trends for children and adolescents. The National Health and Nutrition Examination Surveys, 1963 to 1991. Archives of Pediatrics & Adolescent Medicine. 1995;149(10):1085-1091. [pmid: 7550810].
3 Morgan CM, Tanofsky-Kraff M, Wilfley DE, Yanovski JA. Childhood obesity. Child & Adolescent Psychiatric Clinics of North America. 2002;11(2):257-278. [pmid: 12109321].
4 Sokol RJ. The chronic disease of childhood obesity: the sleeping giant has awakened. J Pediatr. 2000;136(6):711-713.
5 Flegal KM. The obesity epidemic in children and adults: current evidence and research issues. Med Sci Sports Exerc. 1999;31(11 Suppl):S509-S514. [pmid: 10593520].
6 Kohn M, Booth M. The worldwide epidemic of obesity in adolescents. Adolescent Medicine State of the Art Reviews. 2003;14(1):1-9.
7 Lobstein T, Baur L, Uauy R. Obesity in children and young people: a crisis in public health. Obes Rev. 2004;5(Suppl 1):4-85. [pmid: 15096099].
8 Barlow SE, Dietz WH. Obesity evaluation and treatment: Expert Committee recommendations. The Maternal and Child Health Bureau, Health Resources and Services Administration and the Department of Health and Human Services. Pediatrics. 1998;102(3):E29. [pmid: 9724677].
9 Himes JH, Dietz WH. Guidelines for overweight in adolescent preventive services: recommendations from an expert committee. The Expert Committee on Clinical Guidelines for Overweight in Adolescent Preventive Services. Am J Clin Nutr. 1994;59(2):307-316. [pmid: 8310979].
10 Troiano RP, Flegal KM. Overweight children and adolescents: description, epidemiology, and demographics. Pediatrics. 1998;101(3 Pt 2):497-504. [pmid: 12224656].
11 Koplan JP, Dietz WH. Caloric imbalance and public health policy. JAMA. 1999;282(16):1579-1581. [pmid: 10546699].
12 Dwyer JT, Stone EJ, Yang M, Webber LS, Must A, Feldman HA, et al. Prevalence of marked overweight and obesity in a multiethnic pediatric population: findings from the Child and Adolescent Trial for Cardiovascular Health (CATCH) study. Journal of the American Dietetic Association. 2000;100(10):1149-1156. [pmid: 11043699].
13 Must A, Strauss RS. Risks and consequences of childhood and adolescent obesity. Int J Obes Relat Metab Disord. 1999;23(Suppl 2):S2-S11. [pmid: 10340798].
14 Must A. Morbidity and mortality associated with elevated body weight in children and adolescents. Am J Clin Nutr. 1996;63(3 Suppl):445S-447S. [pmid: 8615339].
15 Reilly JJ, Methven E, McDowell ZC, Hacking B, Alexander D, Stewart L, et al. Health consequences of obesity. Arch Dis Child. 2003;88(9):748-752. [pmid: 12937090]. [pmcid: 1719633].
16 Zametkin AJ, Zoon CK, Klein HW, Munson S. Psychiatric aspects of child and adolescent obesity: a review of the past 10 years. J Am Acad Child Adolesc Psychiatry. 2004;43(2):134-150. [pmid: 14726719].
17 Must A, Anderson SE. Effects of obesity on morbidity in children and adolescents. Nutr Clin Care. 2003;6(1):4-12. [pmid: 12841425].
18 Rodriguez MA, Winkleby MA, Ahn D, Sundquist J, Kraemer HC. Identification of population subgroups of children and adolescents with high asthma prevalence: findings from the Third National Health and Nutrition Examination Survey. Archives of Pediatrics & Adolescent Medicine. 2002;156(3):269-275. [pmid: 11876672].
19 Kelsey JL. Epidemiology of slipped capital femoral epiphysis: a review of the literature. Pediatrics. 1973;51(6):1042-1050. [pmid: 4351019].
20 Silvestri JM, Weese-Mayer DE, Bass MT, Kenny AS, Hauptman SA, Pearsall SM. Polysomnography in obese children with a history of sleep-associated breathing disorders. Pediatr Pulmonol. 1993;16(2):124-129. [pmid: 8367218].
21 Mallory GB Jr, Fiser DH, Jackson R. Sleep-associated breathing disorders in morbidly obese children and adolescents. J Pediatr. 1989;115(6):892-897. [pmid: 2585224].
22 Tominaga K, Kurata JH, Chen YK, Fujimoto E, Miyagawa S, Abe I, et al. Prevalence of fatty liver in Japanese children and relationship to obesity. An epidemiological ultrasonographic survey. Dig Dis Sci. 1995;40(9):2002-2009. [pmid: 7555456].
23 Franzese A, Vajro P, Argenziano A, Puzziello A, Iannucci MP, Saviano MC, et al. Liver involvement in obese children. Ultrasonography and liver enzyme levels at diagnosis and during follow-up in an Italian population. Dig Dis Sci. 1997;42(7):1428-1432. [pmid: 9246041].
24 Chan DF, Li AM, Chu WC, Chan MH, Wong EM, Liu EK, et al. Hepatic steatosis in obese Chinese children. Int J Obes Relat Metab Disord. 2004;28(10):1257-1263. [pmid: 15278103].
25 Rosenbloom AL, Joe JR, Young RS, Winter WE. Emerging epidemic of type 2 diabetes in youth. Diabetes Care. 1999;22(2):345-354. [pmid: 10333956].
26 Dabelea D, Hanson RL, Bennett PH, Roumain J, Knowler WC, Pettitt DJ. Increasing prevalence of Type II diabetes in American Indian children. Diabetologia. 1998;41(8):904-910. [pmid: 9726592].
27 Sinha R, Fisch G, Teague B, Tamborlane WV, Banyas B, Allen K, et al. Prevalence of impaired glucose tolerance among children and adolescents with marked obesity. New England Journal of Medicine. 2002;346(11):802-810. [pmid: 11893791].
28 Freedman DS, Srinivasan SR, Berensen GS. Risk of cardiovascular complication. In: Burniat W, Cole T, Lissau I, Poskitt EME, editors. Child and Adolescent Obesity Causes and Consequences, Prevention and Management. Cambridge: Cambridge University Press, 2002: 221–239.
29 Cook S, Weitzman M, Auinger P, Nguyen M, Dietz WH. Prevalence of a metabolic syndrome phenotype in adolescents: findings from the third National Health and Nutrition Examination Survey, 1988-1994. Archives of Pediatrics & Adolescent Medicine. 2003;157(8):821-827. [pmid: 12912790].
30 Weiss R, Dziura J, Burgert TS, Tamborlane WV, Taksali SE, Yeckel CW, et al. Obesity and the metabolic syndrome in children and adolescents. N Engl J Med. 2004;350(23):2362-2374. [pmid: 15175438].
31 Dietz WH. Health consequences of obesity in youth: childhood predictors of adult disease. Pediatrics. 1998;101(3 Pt 2):518-525. [pmid: 12224658].
32 Figueroa-Colon R, Franklin FA, Lee JY, Aldridge R, Alexander L. Prevalence of obesity with increased blood pressure in elementary school-aged children. South Med J. 1997;90(8):806-813. [pmid: 9258307].
33 Dietz WH. Childhood weight affects adult morbidity and mortality. Journal of Nutrition. 1998;128(2 Suppl):411S-414S. [pmid: 9478038].
34 French SA, Story M, Perry CL. Self-esteem and obesity in children and adolescents: a literature review. Obesity Research. 1995;3(5):479-490. [pmid: 8521169].
35 Strauss RS. Childhood obesity and self-esteem. Pediatrics. 2000;105(1):e15. [pmid: 10617752].
36 Strauss RS, Pollack HA. Social marginalization of overweight children. Arch Pediatr Adolesc Med. 2003;157(8):746-752. [pmid: 12912779].
37 Latner JD, Stunkard AJ. Getting worse: the stigmatization of obese children. Obes Res. 2003;11(3):452-456. [pmid: 12634444].
38 Schwimmer JB, Burwinkle TM, Varni JW. Health-related quality of life of severely obese children and adolescents. JAMA. 2003;289(14):1813-1819. [pmid: 12684360].
39 Parsons TJ, Power C, Logan S, Summerbell CD. Childhood predictors of adult obesity: a systematic review. Int J Obes Relat Metab Disord. 1999;23(Suppl 8):S1-S107. [pmid: 10641588].
40 Sturm R. The effects of obesity, smoking, and drinking on medical problems and costs. Obesity outranks both smoking and drinking in its deleterious effects on health and health costs. Health Aff (Millwood). 2002;21(2):245-253. [pmid: 11900166].
41 Fontaine KR, Redden DT, Wang C, Westfall AO, Allison DB. Years of life lost due to obesity. JAMA. 2003;289(2):187-193. [pmid: 12517229].
42 Mokdad AH, Marks JS, Stroup DF, Gerberding JL. Actual causes of death in the United States, 2000. JAMA. 2004;291(10):1238-1245. [pmid: 15010446].
43 Wang G, Dietz WH. Economic burden of obesity in youths aged 6 to 17 years: 1979-1999. Pediatrics. 2002;109(5):E81. [pmid: 11986487].
44 Tershakovec AM, Watson MH, Wenner WJ Jr, Marx AL. Insurance reimbursement for the treatment of obesity in children. Journal of Pediatrics. 1999;134(5):573-578. [pmid: 10228292].
45 Poskitt EM. Defining childhood obesity: the relative body mass index (BMI). European Childhood Obesity group. Acta Paediatr. 1995;84(8):961-963. [pmid: 7488831].
46 Oken E, Lightdale JR. Updates in pediatric nutrition. Curr Opin Pediatr. 2000;12(3):282-290. [pmid: 10836167].
47 Lohman T. Advances in Body Composition Assessment. 3 ed. Champaign, IL: Human Kinetics Publishers, 1992.
48 Lohman TG. Applicability of body composition techniques and constants for children and youths. Exerc Sport Sci Rev. 1986;14:325-357. [pmid: 3525188].
49 Goran MI. Measurement issues related to studies of childhood obesity: assessment of body composition, body fat distribution, physical activity, and food intake. Pediatrics. 1998;101(3 Pt 2):505-518. [pmid: 12224657].
50 Daniels SR, Khoury PR, Morrison JA. The utility of body mass index as a measure of body fatness in children and adolescents: differences by race and gender. Pediatrics. 1997;99(6):804-807. [pmid: 9164773].
51 Maynard LM, Wisemandle W, Roche AF, Chumlea WC, Guo SS, Siervogel RM. Childhood body composition in relation to body mass index. Pediatrics. 2001;107(2):344-350. [pmid: 11158468].
52 Ellis D. Growth and renal function after steroid-free tacrolimus-based immunosuppression in children with renal transplants. Pediatric Nephrology. 2000;14(7):689-694. [pmid: 10912544].
53 Wells JC, Fuller NJ, Dewit O, Fewtrell MS, Elia M, Cole TJ. Four-component model of body composition in children: density and hydration of fat-free mass and comparison with simpler models. Am J Clin Nutr. 1999;69(5):904-912. [pmid: 10232629].
54 Kuczmarski RJ. Trends in body composition for infants and children in the U.S. Crit Rev Food Sci Nutr. 1993;33(45):375-387. [pmid: 8357500].
55 Dietz WH, Bellizzi MC. Introduction: the use of body mass index to assess obesity in children. Am J Clin Nutr. 1999;70(1):123S-125S. [pmid: 10419414].
56 Garn SM, Leonard WR, Hawthorne VM. Three limitations of the body mass index. Am J Clin Nutr. 1986;44(6):996-997. [pmid: 3788846].
57 Kimm SY, Barton BA, Obarzanek E, McMahon RP, Sabry ZI, Waclawiw MA, et al. Racial divergence in adiposity during adolescence: The NHLBI Growth and Health Study. Pediatrics. 2001;107(3):E34. [pmid: 11230615].
58 Cole TJ, Bellizzi MC, Flegal KM, Dietz WH. Establishing a standard definition for child overweight and obesity worldwide: international survey. BMJ. 2000;320(7244):1240-1243. [pmid: 10797032]. [pmcid: 27365].
59 Dietz WH, Robinson TN. Use of the body mass index (BMI) as a measure of overweight in children and adolescents. J Pediatr. 1998;132(2):191-193. [pmid: 9506622].
60 Cole TJ. Children grow and horses race: is the adiposity rebound a critical period for later obesity?. BMC Pediatr. 2004;4(1):6. [pmid: 15113440]. [pmcid: 394330].
61 Kuczmarski RJ, Ogden CL, Guo SS, Grummer-Strawn LM, Flegal KM, Mei Z et al. 2000 CDC Growth Charts for the United States: methods and development. Vital Health Stat 11 2002;(246):1–190.
62 Use and interpretation of anthropometric indicators of nutritional status. WHO Working Group. Bull World Health Organ 1986;64(6):929–941
63 Ellis KJ. Measuring body fatness in children and young adults: comparison of bioelectric impedance analysis, total body electrical conductivity, and dual-energy X-ray absorptiometry. Int J Obes Relat Metab Disord. 1996;20(9):866-873. [pmid: 8880356].
64 Reilly JJ, Dorosty AR, Emmett PM. Identification of the obese child: adequacy of the body mass index for clinical practice and epidemiology. Int J Obes Relat Metab Disord. 2000;24(12):1623-1627. [pmid: 11126215].
65 Reilly JJ, Wilson ML, Summerbell CD, Wilson DC. Obesity: diagnosis, prevention, and treatment; evidence based answers to common questions. Arch Dis Child. 2002;86(6):392-394. [pmid: 12023163]. [pmcid: 1762983].
66 Himes JH. Agreement among anthropometric indicators identifying the fattest adolescents. Int J Obes Relat Metab Disord. 1999;23(Suppl 2):S18-S21. [pmid: 10340800].
67 U.S. Preventive Services Task Force. Guide to clinical preventive services. 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion, 1996.
68 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
69 Haddock CK, Shadish WR, Klesges RC, Stein RJ. Treatments for childhood and adolescent obesity. Ann Behav Med. 1994;16(3):235-244.
70 Epstein LH, Roemmich JN, Raynor HA. Behavioral therapy in the treatment of pediatric obesity. Pediatr Clin North Am. 2001;48(4):981-993. [pmid: 11494647].
71 Glenny AM, O'Meara S, Melville A, Sheldon TA, Wilson C. The treatment and prevention of obesity: a systematic review of the literature. Int J Obes Relat Metab Disord. 1997;21(9):715-737. [pmid: 9376884].
72 Summerbell CD, Ashton V, Campbell KJ, Edmunds L, Kelly S, Waters E. Interventions for treating obesity in children. Cochrane Database of Systematic Reviews 2003;(3):CD001872.
73 Reilly JJ, McDowell ZC. Physical activity interventions in the prevention and treatment of paediatric obesity: systematic review and critical appraisal. Proceedings of the Nutrition Society. 2003;62(3):611-619. [pmid: 14692597].
74 McLean N, Griffin S, Toney K, Hardeman W. Family involvement in weight control, weight maintenance and weight-loss interventions: a systematic review of randomised trials. International Journal of Obesity & Related Metabolic Disorders. 2003;27(9):987-1005. [pmid: 12917703].
75 Ogden CL, Flegal KM, Carroll MD, Johnson CL. Prevalence and trends in overweight among US children and adolescents, 1999-2000. JAMA. 2002;288(14):1728-1732. [pmid: 12365956].
76 Flegal KM, Ogden CL, Wei R, Kuczmarski RL, Johnson CL. Prevalence of overweight in US children: comparison of US growth charts from the Centers for Disease Control and Prevention with other reference values for body mass index. American Journal of Clinical Nutrition. 2001;73(6):1086-1093. [pmid: 11382664].
77 Hedley AA, Ogden CL, Johnson CL, Carroll MD, Curtin LR, Flegal KM. Prevalence of overweight and obesity among US children, adolescents, and adults, 1999-2002. JAMA. 2004;291(23):2847-2850. [pmid: 15199035].
78 Zephier E, Himes JH, Story M. Prevalence of overweight and obesity in American Indian School children and adolescents in the Aberdeen area: a population study. Int J Obes Relat Metab Disord. 1999;23(Suppl 2):S28-S30. [pmid: 10340802].
79 Flegal KM, Carroll MD, Kuczmarski RJ, Johnson CL. Overweight and obesity in the United States: prevalence and trends, 1960-1994. Int J Obes Relat Metab Disord. 1998;22(1):39-47. [pmid: 9481598].
80 Strauss RS, Pollack HA. Epidemic increase in childhood overweight, 1986-1998. JAMA. 2001;286(22):2845-2848. [pmid: 11735760].
81 Ellis KJ. Human body composition: in vivo methods. Physiol Rev. 2000;80(2):649-680. [pmid: 10747204].
82 Dai S, Labarthe DR, Grunbaum JA, Harrist RB, Mueller WH. Longitudinal analysis of changes in indices of obesity from age 8 years to age 18 years. Project HeartBeat!. American Journal of Epidemiology. 2002;156(8):720-729. [pmid: 12370160].
83 Lauer RM, Lee J, Clarke WR. Predicting adult cholesterol levels from measurements in childhood and adolescence: the Muscatine Study. Bulletin of the New York Academy of Medicine. 1989;65(10):1127-1142. [pmid: 2629967]. [pmcid: 1807893].
84 Guo SS, Roche AF, Chumlea WC, Gardner JD, Siervogel RM. The predictive value of childhood body mass index values for overweight at age 35 y. American Journal of Clinical Nutrition. 1994;59(4):810-819. [pmid: 8147324].
85 Clarke WR, Lauer RM. Does childhood obesity track into adulthood?. Crit Rev Food Sci Nutr. 1993;33(45):423-430. [pmid: 8357505].
86 Hulman S, Kushner H, Katz S, Falkner B. Can cardiovascular risk be predicted by newborn, childhood, and adolescent body size? An examination of longitudinal data in urban African Americans. Journal of Pediatrics. 1998;132(1):90-97. [pmid: 9470007].
87 Wattigney WA, Webber LS, Srinivasan SR, Berenson GS. The emergence of clinically abnormal levels of cardiovascular disease risk factor variables among young adults: the Bogalusa Heart Study. Preventive Medicine. 1995;24(6):617-626. [pmid: 8610086].
88 Gortmaker SL, Must A, Perrin JM, Sobol AM, Dietz WH. Social and economic consequences of overweight in adolescence and young adulthood. New England Journal of Medicine. 1993;329(14):1008-1012. [pmid: 8366901].
89 Freedman DS, Khan LK, Dietz WH, Srinivasan SR, Berenson GS. Relationship of childhood obesity to coronary heart disease risk factors in adulthood: the Bogalusa Heart Study. Pediatrics. 2001;108(3):712-718. [pmid: 11533341].
90 Guo SS, Wu W, Chumlea WC, Roche AF. Predicting overweight and obesity in adulthood from body mass index values in childhood and adolescence. American Journal of Clinical Nutrition. 2002;76(3):653-658. [pmid: 12198014].
91 Freedman DS, Khan LK, Serdula MK, Dietz WH, Srinivasan SR, Berenson GS. Inter-relationships among childhood BMI, childhood height, and adult obesity: the Bogalusa Heart Study. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 2004;28(1):10-16. [pmid: 14652621].
92 Daniels S. Pharmacological treatment of obesity in paediatric patients. Paediatric Drugs. 2001;3(6):405-410. [pmid: 11437185].
93 Whitlock EP, Orleans CT, Pender N, Allan J. Evaluating primary care behavioral counseling interventions: an evidence-based approach. Am J Prev Med. 2002;22(4):267-284. [pmid: 11988383].
94 Berkowitz RI, Wadden TA, Tershakovec AM, Cronquist JL. Behavior therapy and sibutramine for the treatment of adolescent obesity: a randomized controlled trial. JAMA. 2003;289(14):1805-1812. [pmid: 12684359].
95 Duffy G, Spence SH. The effectiveness of cognitive self-management as an adjunct to a behavioural intervention for childhood obesity: a research note. J Child Psychol Psychiatry. 1993;34(6):1043-1050. [pmid: 8408368].
96 Ebbeling CB, Leidig MM, Sinclair KB, Hangen JP, Ludwig DS. A reduced-glycemic load diet in the treatment of adolescent obesity. Archives of Pediatrics & Adolescent Medicine. 2003;157(8):773-779. [pmid: 12912783].
97 Epstein LH, Wing RR, Koeske R, Valoski A. A comparison of lifestyle exercise, aerobic exercise, and calisthenics on weight loss in obese children. Behavior Therapy. 1985;16(4):345-356.
98 Epstein LH, Wing RR, Penner BC, Kress MJ. Effect of diet and controlled exercise on weight loss in obese children. J Pediatr. 1985;107(3):358-361. [pmid: 4032130].
99 Epstein LH, Wing R, Woodall K, Penner BC, Kress MJ, Koeske R. Effects of family-based behavioral treatment on obese 5-to-8-year-old children. Behavior Therapy. 1985;16(2):205-212.
100 Epstein LH, McKenzie SJ, Valoski A, Klein KR, Wing RR. Effects of mastery criteria and contingent reinforcement for family-based child weight control. Addictive Behaviors. 1994;19(2):135-145. [pmid: 8036961].
101 Epstein LH, Valoski AM, Vara LS, McCurley J, Wisniewski L, Kalarchian MA, et al. Effects of decreasing sedentary behavior and increasing activity on weight change in obese children 3814. Health Psychology. 1995;14(2):109-115. [pmid: 7789345].
102 Epstein LH, Paluch RA, Gordy CC, Dorn J. Decreasing sedentary behaviors in treating pediatric obesity. Arch Pediatr Adolesc Med. 2000;154(3):220-226. [pmid: 10710017].
103 Epstein LH, Paluch RA, Gordy CC, Saelens BE, Ernst MM. Problem solving in the treatment of childhood obesity. Journal of Consulting & Clinical Psychology. 2000;68(4):717-721. [pmid: 10965646].
104 Epstein LH, Paluch RA, Raynor HA. Sex differences in obese children and siblings in family-based obesity treatment. Obesity Research. 2001;9(12):746-753. [pmid: 11743058].
105 Flodmark CE, Ohlsson T, Ryden O, Sveger T. Prevention of progression to severe obesity in a group of obese schoolchildren treated with family therapy. Pediatrics. 1993;91(5):880-884. [pmid: 8474806].
106 Golan M, Fainaru M, Weizman A. Role of behaviour modification in the treatment of childhood obesity with the parents as the exclusive agents of change. Int J Obes Relat Metab Disord. 1998;22(12):1217-1224. [pmid: 9877257].
107 Graves T, Meyers AW, Clark L. An evaluation of parental problem-solving training in the behavioral treatment of childhood obesity. J Consult Clin Psychol. 1988;56(2):246-250. [pmid: 3372833].
108 Israel AC, Stolmaker L, Andrian CA. The effects of training parents in general child management skills on a behavioral weight loss program for children. Behavior Therapy. 1985;16:169-180.
109 Israel AC, Guile CA, Baker JE, Silverman WK. An evaluation of enhanced self-regulation training in the treatment of childhood obesity. Journal of Pediatric Psychology. 1994;19(6):737-749. [pmid: 7830214].
110 Gutin B, Barbeau P, Owens S, Lemmon CR, Bauman M, Allison J, et al. Effects of exercise intensity on cardiovascular fitness, total body composition, and visceral adiposity of obese adolescents. American Journal of Clinical Nutrition. 2002;75(5):818-826. [pmid: 11976154].
111 Kang HS, Gutin B, Barbeau P, Owens S, Lemmon CR, Allison J, et al. Physical training improves insulin resistance syndrome markers in obese adolescents. Medicine & Science in Sports & Exercise. 2002;34(12):1920-1927. [pmid: 12471297].
112 Mellin LM, Slinkard LA, Irwin CE Jr. Adolescent obesity intervention: validation of the SHAPEDOWN program 3987. Journal of the American Dietetic Association. 1987;87(3):333-338. [pmid: 3819254].
113 Saelens BE, Sallis JF, Wilfley DE, Patrick K, Cella JA, Buchta R. Behavioral weight control for overweight adolescents initiated in primary care. Obesity Research. 2002;10(1):22-32. [pmid: 11786598].
114 Senediak C, Spence SH. Rapid versus gradual scheduling of therapeutic contact in a family based behavioural weight control programme for children. Behavioural Psychotherapy. 1985;13(4):265-287.
115 Wadden TA, Stunkard AJ, Rich L, Rubin CJ, Sweidel G, McKinney S. Obesity in black adolescent girls: a controlled clinical trial of treatment by diet, behavior modification, and parental support 3928. Pediatrics. 1990;85(3):345-352. [pmid: 2304788].
116 White MA. Mediators of weight loss in an Internet-based intervention for African-American adolescent girls. Louisiana State University, 2003.
117 Epstein LH, Valoski A, Wing RR, McCurley J. Ten-year outcomes of behavioral family-based treatment for childhood obesity. Health Psychol. 1994;13(5):373-383. [pmid: 7805631].
118 Robinson TN. Behavioural treatment of childhood and adolescent obesity. International Journal of Obesity & Related Metabolic Disorders 1999; 23:Suppl-7.
119 Jeffery RW, Drewnowski A, Epstein LH, Stunkard AJ, Wilson GT, Wing RR, et al. Long-term maintenance of weight loss: current status. Health Psychol. 2000;19(1 Suppl):5-16. [pmid: 10709944].
120 Yanovski JA. Intensive therapies for pediatric obesity. Pediatric Clinics of North America. 2001;48(4):1041-1053. [pmid: 11494637].
121 McTigue KM., Harris R, Hemphill MB, Bunton AJ, Lux LJ, Sutton S et al. Screening and interventions for overweight and obesity in adults. Systemic Evidence Review No. 21 (prepared by the Research Triangle Institute, University of North Carolina, Evidence-based Practice Center under Contract No. 290-97-0011). Rockville, MD: Agency for Healthcare Research and Quality, 2003.
122 Epstein LH, Paluch RA, Saelens BE, Ernst MM, Wilfley DE. Changes in eating disorder symptoms with pediatric obesity treatment. Journal of Pediatrics. 2001;139(1):58-65. [pmid: 11445795].
123 Inge TH, Garcia V, Daniels S, Langford L, Kirk S, Roehrig H, et al. A multidisciplinary approach to the adolescent bariatric surgical patient. Journal of Pediatric Surgery. 2004;39(3):442-447. discussion 446–447. [pmid: 15017567].
124 Stanford A, Glascock JM, Eid GM, Kane T, Ford HR, Ikramuddin S, et al. Laparoscopic Roux-en-Y gastric bypass in morbidly obese adolescents. Journal of Pediatric Surgery. 2003;38(3):430-433. [pmid: 12632362].
125 Strauss RS, Bradley LJ, Brolin RE. Gastric bypass surgery in adolescents with morbid obesity. J Pediatr. 2001;138(4):499-504. [pmid: 11295712].
126 Charney E. Childhood obesity: the measurable and the meaningful. J Pediatr. 1998;132(2):193-195. [pmid: 9506623].
127 Stettler N. Comment: the global epidemic of childhood obesity: is there a role for the paediatrician?. Obes Rev. 2004;5(Suppl 1):1-3. [pmid: 15096098].
128 Gruen RL, Pearson SD, Brennan TA. Physician-citizens—public roles and professional obligations. JAMA. 2004;291(1):94-98. [pmid: 14709581].
129 Flegal KM, Graubard BI, Williamson DF, Gail MH. Excess deaths associated with underweight, overweight, and obesity. JAMA. 2005;293(15):1861-1867. [pmid: 15840860].
130 Pi-Sunyer FX. Medical hazards of obesity. Ann Intern Med. 1993;119(7 Pt 2):655-660. [pmid: 8363192].
131 Stunkard A. Diet, exercise and behavior therapy: A cautionary tale. Obes Res. 1996;4:293-294. [pmid: 8732964].
132 Whitaker RC. Obesity prevention in pediatric primary care: four behaviors to target. Arch Pediatr Adolesc Med. 2003;157(8):725-727. [pmid: 12912775].
133 Campbell K, Waters E, O'Meara S, Kelly S, Summerbell C. Interventions for preventing obesity in children. Cochrane Database of Systematic Reviews 2003;(1).
134 Krempf M, Louvet JP, Allanic H, Miloradovich T, Joubert JM, Attali JR. Weight reduction and long-term maintenance after 18 months treatment with orlistat for obesity. International Journal of Obesity & Related Metabolic Disorders. 2003;27(5):591-597. [pmid: 12704403].
135 Sopher AB, Thornton JC, Wang J, Pierson RN Jr, Heymsfield SB, Horlick M. Measurement of percentage of body fat in 411 children and adolescents: a comparison of dual-energy X-ray absorptiometry with a four-compartment model. Pediatrics. 2004;113(5):1285-1290. [pmid: 15121943].
136 Power C, Lake JK, Cole TJ. Measurement and long-term health risks of child and adolescent fatness. Int J Obes Relat Metab Disord. 1997;21(7):507-526. [pmid: 9226480].
137 Robinson TN. Defining obesity in children and adolescents: clinical approaches. Critical Reviews in Food Science & Nutrition. 1993;33(45):313-320. [pmid: 8357490].