# Acknowledgments

This Evidence Synthesis was funded by the Agency for Healthcare Research and Quality (AHRQ) for the U.S. Preventive Services Task Force (USPSTF). We acknowledge AHRQ's continuing support through Helen Burstin, Director for Primary Care, Prevention and Clinical Partnership (home of the USPSTF), and we acknowledge the contributions of Gurvaneet Randhawa, MD, MPH, Task Order Officer, AHRQ, and Iris Mabry, MD, Medical Officer, AHRQ. Members of the USPSTF who served as leads for this project include: Janet Allan, PhD, RN, CS, FAAN; Mark Johnson, MD, MPH; Jonathan Klein, MD, MPH; Virginia Moyer, MD, MPH; Judith Ockene, PhD; Steven Teutsch, MD, MPH; and we would also like to acknowledge the guidance from our former USPSTF liaison, C. Tracy Orleans, PhD.

We very much appreciate the contributions of Daphne Plaut, MLS, for bibliographic literature searching advice and execution; Tracy Beil, MS, for assistance with management of references and construction of final tables; and Mary Harper and Debra Burch for secretarial assistance.

We are especially grateful for the advice and guidance provided by two of this project's outside experts and peer reviewers: William Dietz, MD, PhD, Centers for Disease Control and Prevention; and John Reilly, PhD, University of Glasgow. Other experts and peer reviewers who also made this a better report through their time and expertise were Laurie Anderson, PhD, Centers for Disease Control and Prevention; Kenneth Ellis, PhD, Baylor College of Medicine; Leonard Epstein, PhD, University of Buffalo; David Katz, MD, MPH, Yale University; Lorene Ritchie, PhD, University of California; Tom Robinson MD, MPH, Stanford University; and Robert Jeffrey, PhD, University of Minnesota. We appreciate the collegial assistance of Margeret Maglione, MPP, and Paul Shekelle, MD, PhD, at the RAND Evidence-based Practice Center and Carolyn Summerbell, PhD, at the University of Teeside, United Kingdom.

## Request for Reprints

Reprints are available from the AHRQ Web site at www.ahrq.gov (click on Preventive Services) and in print through the AHRQ Publications Clearinghouse (call 1-800-358-9295).