# Discussion

## Conclusions

Overweight has at least doubled in children and adolescents in the U.S. over the last 25 years. There is no doubt that this increase represents a major public health concern with the potential for future health risks and growing burdens on the healthcare system. Clinicians who provide health care to children and adolescents may be in an excellent position to address this. In terms of evidence, however, little has changed since a 1998 editorial in the Journal of Pediatrics concluded that, “In the case of obesity, the primary care physician is left in the uncomfortable (but familiar) position of needing to do something now for the patient and family seeking help, regardless of the uncertainty about the nature of the disease and the absence of a cure.” ^126^ Given the nature of the problem, effective solutions will likely require substantial collaboration between the medical and the public health communities. Further understanding of ways to expand the appropriate role of the clinician in community public health, such as through advocating necessary environmental and political changes, would be helpful. ^127,^ ^128^

A major limitation to clinicians' addressing overweight in the broad population of children in medical practice, most of whom are not morbidly overweight, is the uncertain criteria for determining clinically significant overweight. Although BMI is the best clinically available measure of overweight, uncertainty in its application to individual patients remains. This uncertainty is due to limited knowledge of the current and future health impacts of increased BMI in children, and possible limits in the applicability of current BMI cutpoints for overweight to some individual children and adolescents, particularly those of minority race/ethnicity. As stated well by others, “In clinical practice, the variations found in body fat mass and non-fat mass for a given body weight may make any judgment based on weight (adjusted for height and/or for age) unreliable as an estimate of an individual's actual body fat. At higher levels, BMI and the BMI cutoffs may be helpful in informing clinical judgment, but at levels near the norm additional criteria may be needed.” ^7^ Understanding normal variations in body composition with age, sex, race/ethnicity, sexual maturity, and other factors will be critical to accurately defining unhealthy excess fat or other components of overweight, and appropriate measurement methods. Similarly, as has been done elsewhere, examining the sensitivity and specificity of BMI percentile cutoffs for identifying overweight children using large, representative samples of U.S. children of all ages and races/ethnicities would increase our understanding of BMI as a screening tool. ^64^

The risk for overweight children to become overweight or obese adults has been judged as the best available criterion to judge the clinical validity of BMI in the pediatric age group. ^59^ Adult BMI has been clearly associated with morbidity and mortality, particularly at higher BMI levels, ^129^ although there is no single threshold for increased health risks. ^130^ Adolescents who are at or above the 95^th^ percentile for age- and sex-specific BMI clearly have an increased probability of adult obesity, and early interventions may be potentially beneficial. Recent interventions targeting this age group primarily addresses those who are very overweight, with some studies showing short-term (6–12 month) weight-related improvements. The treatment evidence in this age group could be strengthened by larger trials testing generalizable interventions that can demonstrate sustained effects on overweight status, weight-related health outcomes, risk factors. Many trials in adolescents have specifically targeted minorities ^115,^ ^116^ or enrolled reasonable proportions in their studies, ^94,^ ^110,^ ^113^ and this should continue. Trials among adolescents who are mildly overweight, and those more severely affected, are needed.

In contrast, current data suggest that a substantial proportion of children under age 12 or 13, even with BMIs above the 95^th^ percentile, will not develop adult obesity. Children aged 8–12 have been the most studied in terms of overweight treatment, but we still have very limited information about interventions that would be applicable for primary care. No current randomized controlled trial evidence for clinical interventions of any type is available in children two to five years old.

For all ages, there is very limited evidence for overweight treatment that is feasible for primary care delivery or referral. Generalizability from the existing evidence is a major concern. Few studies have taken place in primary care or seem primary care feasible -most have been conducted in research or specialty obesity clinics using non-medical personnel, and are not widely available for primary care referral. Indeed, experts have cautioned that behavioral therapy is not simply the third component in a triad of intervention elements (along with a diet and exercise plan), but represents an expertise-driven approach to improving diet and physical activity using behavioral principles. These principles include patient-specific means of specifying the behavior to be changed, breaking it down into smallest behavioral units, helping the patient to make changes, and monitoring and reinforcing change. ^131^ If larger studies confirm that the behavioral skills and approaches tested thus far are key to success, it will be critical to find a way to create referral clinics or involve clinical team members with expertise in behavioral medicine/psychology in implementing weight control programs. ^131^

Experts recommend referring certain children to pediatric obesity treatment centers for expert management. These include children who are massively overweight (defined through clinical judgment) ^8^ or who have BMI exceeding the 95^th^ percentile with one or more associated severe morbidities that require immediate weight loss. In asymptomatic children with a BMI ≥ 95^th^ percentile, these experts have also recommended an in-depth medical assessment to detect treatable causes of obesity, risk factors, and comorbidities, and to determine need for treatment. For children whose BMI falls between the 85^th^ and 95^th^ percentiles for age and sex, they also recommend clinical evaluations for secondary effects of overweight, such as hypertension and hyperlipidemia. We did not find adequate evidence meeting our criteria to address the impact of BMI screening and/or treatment of overweight (or at risk for overweight) on any of these risk factors or morbidities. It was beyond the scope of our review to systematically evaluate other types of evidence to support these expert recommendations; however, this is an important area for future systematic review.

Experts emphasize talking to families about energy balance behaviors that prevent obesity, promote other aspects of health, and are likely to cause no harms. ^132^ These behaviors include limiting television viewing, encouraging outdoor play, and limiting the consumption of sugar-sweetened soft drinks. For the interested clinician, pragmatic approaches for all children (particularly young children) emphasizing the “healthy lifestyle prescription” approach over targeting overweight identification seem appropriate since we found limited evidence for secondary prevention or treatment. Similarly, others have found limited evidence for the effectiveness of primary prevention in clinical settings. ^133^

Given the current evidence, perhaps BMI measurement in children should be performed as a growth-monitoring tool that may indicate future risk for adult overweight and its attendant morbidities, rather than as a screen for determining current overweight. Children, particularly those under the age of 13, without clinical weight-related morbidities would not necessarily be labeled overweight, but might be considered “at risk” or “at high risk” depending on the BMI level. Experts recommend regular longitudinal monitoring and careful documentation of BMI in children and adolescents. ^134^ Such monitoring will likely prove valuable as our understanding about the predictive value of growth levels and patterns, and overweight status, change over time, and effective ways to address patterns that indicate overweight.

## Limitations of the Literature

In the absence of direct evidence screening's impact on improved weight and health outcomes in children and/or adults, we have evaluated and linked indirect evidence for screening and intervention. In the current literature, evidence linkages between screening and intervention are hampered by divergent definitions of overweight. In the epidemiological research addressing childhood overweight as a risk factor, more recent reports focus on BMI percentiles or z-scores (which can be translated approximately into percentiles), and many use the current CDC growth charts as references. In the treatment literature, few studies use BMI percentiles as weight entry criteria, probably due to the older age of the literature. More recent studies use BMI-based criteria and are more explicit about their references for its use. It is important that a consistent definition of overweight be accepted to encourage rapid progress in our understanding of how to address this critical problem.

Limited evidence on normal body composition in children and adolescents, and lack of criterion standards for adiposity in children, hampered our ability to determine the test characteristics (sensitivity and specificity) of clinically feasible screening tests. The state of the science is changing, ^135^ with evidence comparing diagnostic tests with valid body composition measures beginning to emerge from other countries. This evidence should become more available in U.S. populations in the future. Similarly, weight-related criterion standards with clearly established current or future health consequences for children of both sexes and all ages and races/ethnicities will enable diagnostic test research addressing BMI and other measures. We limited our review of the relationships between childhood weight status (primarily BMI) and adult health consequences / adult obesity to longitudinal U.S. studies. While this may have given us an advantage in minimizing the differences due to overweight definitions, reference standards, and country and population measurement differences, ^136^ such an approach may have unnecessarily eliminated our review of applicable data. Much of this research was based on non-Hispanic whites, which limits applicability to minorities in whom the prevalence of overweight is increasing.

We did not locate adequate longitudinal data relating childhood weight status to childhood health outcomes, and thus did not review it formally. Current literature is primarily cross-sectional, presents relative risks without absolute risks, or reports on the relationship of growth measures (or changes in them over time) to intermediate measures, such as blood pressure or lipids, rather than health outcomes.

The literature or pediatric obesity is growing due to enormous public health and scientific interest, which makes it challenging to ensure comprehensiveness. It is possible that some relevant literature was missed or excluded through our methods. Reviewing this literature is complicated by the rapid evolution in appropriate methods to define, diagnose, monitor, and intervene with childhood and adolescent overweight and obesity for different ages, sexes, and racial/ethnic and cultural groups. Although we made an effort to comprehensively review several areas of the literature, some areas were not reviewed. We did not review any evidence on children under the age of two, although this is an active area for research. We did not attempt to examine risk factors for childhood overweight, but note that others have recently done so. ^39^ Similarly, research about approaches to changing daily life habits, dietary intake, and physical activity may help address and prevent pediatric overweight, including intriguing evaluations of television and overweight.

## Future Research

There are critical research gaps in answering the most basic questions needed to enable clinicians to engage strategies to prevent current and future weight-related morbidities in children. Despite the fact that many of these gaps were identified over 10 years ago, ^137^ little subsequent research has addressed the most clinically relevant questions. In addition to the clinical research already underway to address childhood overweight prevention and treatment (Table 7), we strongly urge the research community to prioritize research studies that will supply needed evidence to address the key questions formulated for this report in order to inform pragmatic clinical, as well as public health, prevention strategies. Some of these may result from reporting from existing good-quality cross-sectional and longitudinal cohort studies in addition to new studies and clinical trials.

Table 7 Pending Studies / Studies Awaiting Assessment

Study Identification Completion Date, Funding Agency | Trial Name/Title | Participants | Interventions | Study Aim
Epstein, LH, et al | The effect of reinforcement or stimulus control to reduce sedentary behavior in the treatment of pediatric obesity | N/A | N/A | N/A
In press, Health Psychology
Epstein, LH | A Behavioral Economic Approach to Childhood Obesity | 120 obese children, followed for two years | Randomized to one of two groups based on behavioral economic theory or standard family-based behavioral intervention program. | To test an innovative program for pediatric obesity based on behavioral economic theory that provides reinforcement for obese children for alternatives to their usual high-fat/low nutrient density eating.
March 2006
National Institute of Child Health and Human Development (NICHD)
NICHD | Safety and Efficacy of Orlistat in African American and Caucasian Children and Adolescents with Obesity-Related Co morbid Conditions | 12–17 year old African American or Caucasian with BMI above the 95^th^ percentile, evidence of quantifiable obesity-related comorbidities; | Investigation drug: Orlistat | Determine the safety, tolerability, and efficacy of Orlistat in children and adolescent with comorbidities
| | Control group: Healthy children and adolescents with BMI above the 5^th^ but below the 85^th^ percentile.
Reilly, John J | The Scottish Childhood Obesity Treatment Trial (SCOTT) | 6–10 year old children | 140 children randomized to treatment (24-week behavioral change program) or control group (typical care) | Primary outcome is change in BMI, secondary outcomes are physical activity, blood pressure, body fat distribution, body fatness, and adverse effects.
Reynolds, Kim D. | Obesity Prevention Tailored for Health | Families with children 10–11 years old | A motivational Interviewing protocol will be developed for delivery to the parents | Measurements of diet, psychosocial variables, fruit and vegetable availability, and BMI will be completed on children and one parent
June 2005
National Cancer Institute
Ariza, Adolfo J. | Tools to Improve Nutritional Health in Primary Care (pilot study) | Two diverse medical practices, one with a majority of white, privately insured patients and the other a community health center serving low-income African American and Hispanic patients. | The program includes a practice educational intervention and the use of a computerized system using newly developed software that has the ability to track growth and provide personalized handouts about child nutrition according to child age and nutritional status categories. | Determine changes effected by the program in the rates of identification of overweight or at risk for overweight children, in the provision of counseling on healthy behaviors, and in-patient flow.
December 2004
AHRQ
Barlow, Sarah E. | Improving Obesity Care in Pediatric Offices | 6–16-year-olds | Intervention is with pediatricians | To improve communication about childhood and adolescent obesity in the offices of pediatricians.
August 2005
AHRQ
Saelens, Brian E. | Body Fat and Hormones in Adolescent Obesity Treatment | NR | NR | Examining the time course of total body fat and intra-abdominal fat accretion through early puberty among already overweight youth. Investigate the differential impact of providing similar behavioral weight control intervention to overweight youth at different time periods of intra-abdominal fat mass accumulation.
March 2007
National Institute of Diabetes and Digestive and Kidney Diseases
Wilfley, Denise E. | Childhood Obesity Treatment: A Maintenance Approach | 216 9–11-year-old children with one obese parent | Two strategies designed to improve the long-term maintenance of weight loss in children | The study will examine whether the content of the maintenance sessions or extended treatment is important in improving long-term maintenance.
July 2004
NICHD
Golan, M. | Targeting Parents Exclusively in the Treatment of Childhood Obesity: Long-Term Results | 50 of the 60 children from the original study located 7 years later. Now 14–19 years of age. | Two different target groups attended sessions (parent-only group, child-only group) to test the effect on children's percent overweight. | To report the long-term change in children's overweight following a family-based health-centered approach where only parents were targeted compared with a control intervention where only children were targeted.
February 2004
No outside funding
Epstein, H | The Effect of Reinforcement or Stimulus Control to Reduce Sedentary Behavior in the Treatment of Pediatric Obesity | 72 families with a child 8–12 years old with BMI > 85^th^ percentile. | Two treatment groups: reinforced reduced sedentary behavior or stimulus control of sedentary behaviors. | To determine whether different methods of reducing targeted sedentary behaviors as associated with differences in the pattern of change in behaviors and in percentage overweight change.
2004
NICHD

In order to address the direct and indirect impact of clinical screening programs on health outcomes, an established definition of overweight level(s) based on documented health effects is urgently needed. Common and agreed-upon definitions for overweight and obesity within the U.S., if not internationally, must be established to facilitate the integration of epidemiological and clinical research and the speed with which we can learn. Clinicians will also need to understand how risks and morbidities vary with overweight levels, age, and other factors in order to support subsequent screening in those identified as overweight. Key needed research includes:

a Diagnostic accuracy testing for BMI (sensitivity and specificity) compared to a valid gold standard in detecting clinically significant overweight in children and adolescents.
b Refine single and repeated BMI measures over time, in conjunction with other pragmatic clinical measures, for use in children. This may include creating growth references for children eight and older to include maturational status, confirming that current growth references adequately apply to minority children known or suspected to have different growth trajectories and body compositions (black, Asian, Native American, and Mexican American children), and developing and validating approaches to supplement modestly elevated BMI measurements with added medical measurements or risk factor status. The latter might include parental obesity, physical examination, laboratory tests, and/or anthropometric measures, such as waist-hip ratio, triceps skinfold, or clinical adiposity measures such as bioelectrical impedance assay, once they are sufficiently validated.
c Continued investigation of growth trajectories and susceptible periods for overweight development and their role as predictors of future morbidity and adult overweight and obesity. True “growth curves” for BMI and other measures should be created from longitudinal data and related to current and subsequent morbidities, as growth patterns may be more relevant than measurement at a single time point. Reporting of tracking between childhood BMI (single or repeated BMI measures, or growth patterns) and adult weight status should demonstrate similarities and differences due to age, sex, and race/ethnicity. Prognostic studies of childhood overweight and adult morbidities should control for adult weight status.
d Better understanding of overweight-associated risks in children and adolescents and how they vary by age, gender, and racial/ethnic subgroups in order to develop realistic goals and strategies to improve short-term and long-term health in an environment conducive to high levels of overweight. Research is needed to establish the prevalence of, and prospective risk for, medical and psychosocial risk factors and morbidities by various weight-related measures (such as BMI percentiles) for race-, age-, and sex-specific groups using large, racially and ethnically representative samples of children and adolescents. Clinical measurement strategies should account for differences in body composition due to race/ethnicity, maturational status, athletic development, and linear growth, ^50^ particularly when these affect weight-related health consequences.
e Clear evidence-based approaches to medical and psychological screening in children identified as overweight at various ages, including research on the benefits of screening for and managing cardiovascular and diabetes disease risk factors in overweight adolescents.
f Clinical research on the harms and acceptability of overweight screening.

Intervention programs to reduce weight-related risks and morbidities in children and adolescents identified through screening programs are required to justify screening. These must be feasible for primary care delivery or referral and should address children at all overweight levels. Key needed research includes:

a Experimental and quasi-experimental studies of child and adolescent obesity treatment on BMI and childhood and adult psychosocial and health outcomes, ^31^ with a priority on adolescents.
b Clinical or observational research on changes in morbidity among children and adolescents who lose weight and maintain this loss or those that regain it in adulthood. ^31^
c Clinical research on the long-term maintenance of healthy weight changes in children and adolescents.
d Research on practical approaches to overweight treatment that can be implemented in pediatrician and family practice offices using novel adaptations and partnerships in the health care system and the community. ^127^
e Randomized clinical trials on clinical approaches by pediatricians and family practitioners to overweight prevention in children and adolescents, and their interaction with population approaches, such as school- and family-based approaches.
f Clinical research on the harms and acceptability of overweight treatments.