# Results

## Key Question 1. Is there direct evidence that screening for overweight in children/adolescents improves age-appropriate behavioral or physiologic measures, or health outcomes?

Our searches found no studies, nor did examination of all individual trials included in previous systematic evidence reviews. ^65,^ ^71^ – ^74^

## Key Question 2a. What are appropriate standards for overweight in children/adolescents and what is the prevalence of overweight based on these?

Eight nationally representative health examination surveys that included children have been conducted in the United States since 1963 (Appendix R). ^54,^ ^75^ These surveys have gathered a variety of anthropometric measures on children aged two months to 18 years that can be used to provide growth references (a tool for providing a common basis for purposes of comparison) ^62^ for children, as well as trend analyses of changes in the population over time. In order to provide useful trend analyses, measures must be valid, gathered consistently in surveys, and must use a single source for comparison. Due to one or more of these limitations, almost all data on prevalence and trends in U.S. children are based on BMI measures calculated from standardized weight and height information. ^1^

BMI measurements must be compared to a reference population to determine their age- and sex-specific percentile ranking. While many reference datasets for childhood BMI are available, three that are commonly cited in current literature are: 1) NHANES I for children aged 6–19, which has been used widely in the United States and internationally; 2) the CDC's 2000 gender-specific BMI growth charts for children 2 through 19 years (based on National Health Examination Survey [NHES] II and III, NHANES I and II, and NHANES III for children under six years); and 3) the International Obesity Task Force (IOTF) standards for obesity derived from six different countries, including the U.S., for children aged 2 through 18 years to match the adult cutoffs of BMI of 25 (overweight) and 30 (obese) at age 18. ^1^ These three sets of BMI references give similar, but not identical, estimates of the prevalence of overweight in the U.S. ^76^ In this report, we focus on the current prevalence estimates and trend information available from the NHANES program, which uses the CDC's 2000 gender-specific BMI growth charts as their reference dataset. These are widely available to clinicians and provide curves smoothed to the nearest month in the data, rather than the nearest half-year or birthday, and are viewed to be generally preferable for use in the United States. ^76^ NHANES provides the most comprehensive data available on boys and girls aged 6 months through 19 years, and recently includes over-sampling of black and Mexican American children.

### Prevalence

Using BMI ≥ 95^th^ percentile, the prevalence of overweight in 1999-2002 was 10% in two- to five-year-olds and 16% in those six years and older ^77^ (Figure 3). For children two to five years of age, the prevalence was similar between all racial/ethnic subgroups and both sexes, but was lower than the prevalence in older children in the same racial/ethnic subgroups. Among children 6 to 11 years, differences were seen between racial/ethnic subgroups, with significantly more Mexican American (21.8%) and non-Hispanic black (19.8%) children categorized as overweight, compared with non-Hispanic whites (13.5%) (p<.05). Sex-specific differences were also seen, with the highest prevalence of overweight in 6- to 11-year-olds among Mexican American boys (26.5%), which was significantly higher than non-Hispanic black boys (17%), non-Hispanic white boys (14%), and Mexican American girls (17.1%), and similar to that of non-Hispanic black girls (22.8%). Among youth aged 12 to 19 years, significantly more non-Hispanic black (21.1%) and Mexican American (22.5%) children had overweight BMI measurements than non-Hispanic whites (13.7%) (p<.05), with no differences between males and females.

Prevalence of Overweight 1999-2002 % with BMI equal to or greater than 95%with standard error bars ^76^ . Prevalence of Overweight or at Risk for Overweight 1999-2002 % with BMI equal to or greater than 85% with standard error bars ^76^

NHANES does not provide separate estimates for Native American children. In a population-based survey of 12,559 schoolchildren aged 5 to 17 years representing 18 tribes in the Midwest in 1995-1996, the overall age-adjusted prevalence of overweight was significantly greater in males (22.0%, 95% CI 21.0–23.0) than in females (18.0%, 95% CI 17.0–19.0). ^78^ In five-year-olds, the overweight prevalence was not significantly different in boys (16.1%) and girls (11.6%). Between ages 6 and 11 years, overweight prevalence remained similar between sexes, ranging from 12.0% to 24.6% in boys and 15.0% to 20.7% in girls. Beginning at age 12, males had consistently higher prevalence of overweight (20.9% to 25.9%) than females (15.9% to 22.5%).

Given the differences in reporting, it is difficult to directly compare prevalence estimates for Native Americans to other races/ethnicities. However, the overweight prevalence of Native American boys aged 6 to 11 is between that of non-Hispanic blacks (the second-highest prevalence) and the most prevalent group, Mexican Americans. Similarly, for girls 6 to 11, the prevalence of Native American overweight appears to rank between the second-highest (Mexican Americans) and the highest groups (non-Hispanic blacks). In adolescents, a similar ranking is seen in boys and girls, despite the younger age representation of Native American children (12 to 17 years) compared with other races (12 to 19 years). Thus, it appears that Native American children aged 6 to 17 rank as at least the second-highest group in prevalence of overweight among races.

The prevalence of overweight based on BMI changed little between 1960 and 1980 among children and adolescents in the United States. ^1^ Using the same reference population, sex- and age-specific subgroups aged 2–19 years showed an increase in overweight prevalence between the 1988-1994 and 1999-2000 surveys, which was similar to, or greater than, increases during the longer time period between earlier surveys (NHANES II [1976-1980] and NHANES III [1988-1994]). ^75^ In the 6–12 years before 2000, statistically significant increases in the prevalence of BMI measures above the 95^th^ percentile threshold for overweight occurred among all 2- to 5-year-olds (3.1%), all 6- to 11-year-olds (4.0%), and all 12- to 19-year-olds (5.0%), with 12- to 19-year-old boys increasing 4.2% and girls increasing 5.8% (p<.05). When analyzed by race/ethnicity, only non-Hispanic black and Mexican American children exhibited statistically significant increases in prevalence between 1988 and 2000. In Mexican Americans, the prevalence increased 13% in boys, and the prevalence increased 10% in both non-Hispanic black boys and girls in. Among all 12- to 19-year-olds, 11.2% met the adult definition of obesity (BMI of 30 or higher), with rates particularly high among non-Hispanic black females (20%) and Mexican American females (16%). Other data also demonstrate increased severity of excess weight among overweight children, ^79^ especially black and Mexican American children, ^12^ increasing the sense of urgency about childhood overweight. ^80^

Important caveats apply to estimating the prevalence of overweight prevalence and trends among groups other than non-Hispanic whites. Unfortunately, representative national data are unavailable to reliably estimate the prevalence of overweight in children and adolescents of Asian/Pacific Islander descent. While recent surveys such as NHANES 1999-2000 have over-sampled Mexican Americans and non-Hispanic blacks, ^75^ comparable race/ethnicity information for these groups is limited to NHANES III and NHANES 1999-2000, with some supplementation by Hispanic HANES (1982-1984) (Appendix R). Commonly used growth references, such as the CDC's sex-specific BMI-for-age charts, which are based primarily on white and black samples from 1963 through 1980 (through 1994 for those under age 6), ^61^ may inaccurately measure the prevalence of overweight in Mexican American youth ^54^ or in Native Americans. Similarly, blacks are represented but do not make up the majority, and metabolic consequences in blacks, whites, and Hispanics at the same BMI z-score have been shown to differ. ^30^ These same issues could pertain to applying the available growth references to Native Americans. Given the known differences in body composition and growth and development between races, ^47,^ ^57,^ ^81,^ ^82^ and possible differences in the validity of BMI as a proxy for percent body fat in different races, ^50^ it will be important to clarify the health significance of BMI measurements at various ages among boys and girls of racial/ethnic subgroups. ^49^

## Key Question 2b. What clinical screening tests for overweight in childhood are reliable and valid in predicting obesity in adulthood?

We found 19 fair- or good-quality longitudinal cohort studies (in 20 publications) that reported on BMI and other weight status measurements in childhood and adulthood (Table J-1 in Appendix J). BMI measurements tracked as well as or better than other overweight measures, such as Ponderal Index or skinfold measures. We focus on the correlation between BMI measurements in childhood and adulthood (Table 3), and between overweight childhood BMI percentiles and the probability of adult obesity (BMI > 30) (Table 4) in selected fair- to good-quality prospective U.S. studies. ^83^ – ^91^ Single BMI measures track reasonably well from childhood and adolescence (aged 6 to 18) into young adulthood (aged 20 to 37), as evidenced by longitudinal studies showing low to moderate (r = 0.2–0.4) or moderate to high (0.5–0.8) correlations between childhood and adult BMI measures (Table 3). Increased tracking (r ≥ 0.6) is seen in older children (after age eight, particularly when this age represents sexual maturity), in younger children (aged 6 to 12) who are more overweight (usually above the 95^th^ or 98^th^ percentile), and in children with one or more obese parent (also see Appendix J). Data on tracking for children before the age of 12 are not extensive. Sex differences in tracking are not consistent across ages or within age categories. Limited data are available comparing white and black children.

Table 3 Effect of Age and Race on the Correlation of Childhood with Young Adult Body Mass Index (BMI)

Effect of Age on the Correlation of Childhood with Young Adult BMI
Reference | Population | Childhood Age, Years | Males | Females
Guo et al 1994 ^84^ | 100% white (n=555) | 3 | .18 | .22
Lauer et al1989 ^83^ | 100% white (n=109 observations) | 7 to 8 | .57 | .45
Lauer et al 1989 ^83^ | 100% white (n=603 observations) | 9 to 10 | .63 | .61
Clarke and Lauer 1993 ^85^ | 100% white (n=1,286 observations) | 9 to 10 | .61 | .59
Lauer et al 1989 ^83^ | 100% white (n=1,018 observations) | 11 to 12 | .67 | .65
Guo et al 1994 ^84^ | 100% white (n=555) | 13 | .5 | .65
Lauer et al 1989 ^83^ | 100% white (n=1,041 observations) | 13 to 14 | .64 | .68
Clarke and Lauer 1993 ^85^ | 100% white (n=1,104 observations) | 13 to 14 | .7 | .7
Lauer et al 1989 ^83^ | 100% white (n=615 observations) | 17 to 18 | .74 | .73
Clarke and Lauer 1993 ^85^ | 100% white (n=631 observations) | 17 to 18 | .81 | .72
Effect of Race on the Correlation of Childhood with Young Adult BMI
Hulman et al 1998 ^86^ | 100% black (n=137) | 13 | .37
Wattigney et al 1995 ^87^ | 100% black (n=147) | 13 to 17 | .69 | .72
Wattigney et al 1995 ^87^ | 100% white (n=327) | 13 to 17 | .63 | .48
Freedman et al 2004 ^91^ | 67% white (n=2,212) | 14 to 17 | .76 | .73

Table 4 Probability of Adult Obesity (Body Mass Index [BMI] ≥30) Based on Childhood BMI Percentile Measures at Various Ages

Study Identification | Overweight Measure in Childhood, BMI Percentile | Child's Age When Measured | Adult's Age When Measured | Probability of Adult Overweight (Male & Female Combined) | Probability of Adult Overweight (Males) | Probability of Adult Overweight (Females)
Gortmaker et al 1993 ^88^ | > 95 | 16–24 | 23–31 | — | .77* | .66*
(n=10,039)
80% white, 14% black, 6% Hispanic 51% female
Freedman et al 2001 ^89^ | < 50 | 5–17 | 18–37 | .07 | — | —
(n=2617)
67% white, 32% black, 57% female
Freedman et al 2001 ^89^ | 85–94 | 5–17 | 18–37 | .51 | — | —
(as above)
Freedman et al 2001 ^89^ | ≥ 95 | 5–17 | 18–37 | .77 | — | —
(as above)
Guo et al 2002 ^90^ | ≥ 75 | 3 | 35 | — | .1 | .14
(n=347) | ≥ 85 | | | — | .1 | .17
100% white, 52% female | ≥ 95 | | | | .2 | .24
Guo et al 2002 ^90^ | ≥ 75 | 8 | 35 | — | .1 | .16
(as above) | ≥ 85 | | | | .1 | .23
| ≥ 95 | | | | .2 | .46
Guo et al 2002 ^90^ | ≥ 75 | 13 | 35 | — | .2 | .16
(as above) | ≥ 85 | | | | .2 | .27
| ≥ 95 | | | | .5 | .64
Guo et al 2002 ^90^ | ≥ 75 | 18 | 35 | — | .2 | .15
(as above) | ≥ 85 | | | | .3 | .26
| ≥ 95 | | | | .8 | .68

* In this study adult overweight was defined as >95%ile on NHANES.

In terms of childhood overweight tracking to adult obesity, the probability is highest among white overweight males (0.77–0.8) and white overweight females (0.66–0.68) aged 16–18. When considered by age groups (Table 4), a 50% or greater probability of adult obesity (BMI > 30) is primarily reported in children over age 13 whose BMI measures are at or above the age- and sex-specific 95^th^ percentile, with one exception. In the Bogalusa Heart Study (67% white and 32% black), children grouped across ages (5 to 17 years) with BMI levels at or above the 85^th^ percentile had a 0.51–0.77 probability of adult obesity.

## Key Question 2c. What clinical screening tests for overweight in childhood are reliable and valid in predicting poor health outcomes in adulthood?

Although a large number (n=11) of prospective or retrospective U.S. studies examined the risk associated with childhood overweight and adult outcomes—including socioeconomic outcomes, mortality, and a range of adult cardiovascular risk factors and morbidities—these studies rarely controlled for adult BMI, a critical potential confounder. In one that did, ^89^ the apparent association between elevated BMI at age 10 and elevated cardiovascular risk factors in adulthood was eliminated after controlling for adult BMI (also see Appendix K). While these data are useful in illustrating expected health consequences that may occur when childhood obesity persists into adulthood, it is not as useful in determining the level of health risk associated with childhood overweight measures that is independent of adult weight status.

## Key Question 3. Does screening have adverse effects, such as labeling or unhealthy psychological or behavioral consequences?

We found no direct evidence on the harms of screening. Potential harms include labeling, induced self-managed dieting with its negative sequelae, poorer self-concept, poorer health habits, disordered eating, or negative impacts from parental concerns.

## Key Question 4. Do interventions (behavioral counseling, pharmacotherapy, or surgery) that are feasible to conduct in primary care settings or available for primary care referral lead to improved intermediate behavioral or physiologic measures with or without weight-related measures?

Potential interventions to improve weight status in children include behavioral counseling interventions, pharmacotherapy, and surgery. Experts agree that surgical approaches should be considered only in adolescents with extreme and morbid obesity, and that pharmacologic approaches should also be limited to a second-tier approach after failed behavioral counseling. ^92^ We did not limit our intervention studies to U.S. populations, but included interventions from other Western industrialized nations.

### Behavioral Counseling Interventions

The most extensive treatment literature for childhood overweight involves behavioral counseling interventions. Behavioral counseling interventions are those activities delivered by primary care clinicians and related healthcare staff to assist patients in adopting, changing, or maintaining health behaviors proven to affect health outcomes and health status. ^93^ These interventions may occur, all or in part, during routine primary care and may involve both visit-based and outside intervention components, including referral to more intensive clinics in the community. Behavioral counseling interventions reviewed here included behavioral modification special diets, and/or activity components delivered to children and/or parents as individual or in groups.

We considered all trials published since 1985 (n = 22 from 23 publications) that addressed interventions that were feasible for primary care conduct or for primary care referral (including one that combined comprehensive behavioral treatment with pharmacotherapy, described separately below). ^94^ – ^116^ We limited our consideration to post-1985 trials given the dramatic increases in overweight in children that have occurred during the 1980s and 1990s. ^5,^ ^11,^ ^80^ A previous good-quality systematic review covering 16 of these trials concluded that this behavioral counseling treatment literature is limited, due to small sample sizes and marginal-quality trials testing primarily non-comparable interventions delivered in specialty obesity clinic treatment settings to significantly overweight school-aged children (40%–50% above ideal weight) with primarily short-term outcomes. ^72^ We found limited improvement from these conclusions by including six additional studies published in the interim (Table 5). These studies continued to be very small (16 to 82 participants), to primarily analyze treatment completers only, and to examine very different interventions over a relatively short period of time. Studies also tended to target those who were quite overweight (see Figure 4). Inclusion criteria and weight outcome measures tended to be BMI-related more than the earlier literature, likely reflecting the growing consensus about the use of BMI.

Table 5 Randomized Controlled Trials Addressing Overweight in Children and Adolescents

Study Reference | N Randomized | Age | Baseline Measure of Overweight | [underlined: Intervention characteristics*] | | Group | Units of Measure | Study Duration | Outcome at Latest Follow-up Time | P Value for Comparisons between Groups** | Other Outcomes | USPSTF Quality Grade
| Country | % Male | | Components Comprehensive? | Time Period # of Sessions
| | % Non-White | | Parent Participation? | Session Length
| | | | Group vs. Individual | Total Contact Time (min)
Berkowitz et al 2003 ^94^ | 82 adolescents | 13–17 | BMI 37.8 kg/m^2^ (3.8); | BM,D,E | 6 mo (phase I) | Sibutramine | change in BMI (% change from entry BMI) | 6 months | -8.5% | p = 0.001 | P, A | Good
| USA | 33% | BMI z-score: 2.4 (0.2) | yes | 19 (phase I) | Placebo | | | -4.0%
| | 45% | | yes | NR
| | | | G | NR
Duffy and Spence 1993 ^95^ | 29 children | 7–13 | 48.4% overweight | BM,D,E | 8 wk | BT + cognitive self-management | % overweight change | 6 months | -8.9% | n.s. | B | Fair-to-Poor
| Australia | 21% | | yes | 8 | BT + relaxation placebo | | | -9.2%
| | NR, Australian | | yes | 90 in
| | | | NR | 720 min
Ebbeling et al 2003 ^96^ | 16 adolescents | 13–21 | BMI 34.9 kg/m^2^ (reduced glycemic group); | BM,D | 12 mo | Reduced glycemic load diet | absolute change in BMI | 12 months | -1.2 kg/m2 | p < 0.05 | B, P | Fair
| USA | 31% | 37.1 kg/m^2^ (reduced fat diet group) | No | 14 | Reduced fat diet | | | 0.6 kg/m^2^
| | 19% | | No | NR
| | | | NR | NR
Epstein et al 1985 ^97^ | 41 families | 8–12 | 48% overweight | BM,D,E | 12 mo | Lifestyle PA | % overweight change | 24 months | -18.0% | <0.05, lifestyle PA vs. aerobic PA; | B, P | Fair
| USA | 40% | | yes | 18 | Aerobic PA | | | -6.8% | <0.05, lifestyle PA vs. calisthenics PA
| | NR | | yes | NR | Low-intensity calisthenics PA | | | -7.2%
| | | | NR | NR
Epstein et al 1985 ^98^ | 23 children | 8–12 | 48 % overweight | BM,D,E | 12 mo | Diet + PA | % overweight change | 12 months | -25.4% | n.s. | B, P | Fair
| USA | 0% | | yes | NR | Diet alone | | | -18.7%
| | NR | | yes | NR
| | | | NR | NR
Epstein et al 1985 ^99^ | 24 children | 5–8 | 39–42% overweight | BM,D,E | 12 mo | BT | % overweight change | 12 months | -26.3% | < 0.05 | B | Fair
| USA | 0% | | yes | unclear, approx | Education only | | | -11.2%
| | NR | | yes | 26
| | | | G, unclear if I | NR
Epstein et al 1994 ^100^ | 44 families | 8–12 | 59.6% over the 50th%ile for BMI | BM,D,E | 1 yr | Mastery criteria & contingent reinforcement group | % overweight change | 24 months | -15.4% | n.s. | B | Fair
| USA | 26% | | yes | 32 | Comparison group | | | -10.6%
| | NR | | yes | NR
| | | | unclear | NR
Epstein et al 1995 ^101^ | 61 families | 8–12 | 51.8% overweight | BM,D,E | 6 mo | Combined | % overweight change | 12 months | -8.7% | p < 0.05, combined vs. increased PA | B, P | Fair
| USA | 27% | | yes | 18 | Decreased SB | | | -10.3%
| | 4% | | yes | NR | Increased PA | | | -18.7%
| | | | I + G | NR
Epstein et al 2000 ^102^ | 90 families | 8–12 | 62% overweight | BM,D,E | 6 mo | Decreased SB high dose | % overweight change | 24 months | -14.3% | n.s. | B, P | Fair
| USA | 32% | | yes | 20 | Decrease SB low dose | | | -11.6%
| | NR | | yes | 45–60 min | PA high dose | | | -13.2%
| | | | I + G | 900–1200 min | PA low dose | | | -12.4%
Epstein et al 2000 ^103^ / Epstein et al 2001 ^104^ | 67 children | NR, mean (SD) 10.3 (1.1) yrs | BMI 27.4 kg/m^2^ (3.2) | BM,D,E | 6 mo | PS to parent and child | change in BMI z-score | 24 months | -0.5 | p < 0.05, PS to parent and child vs. no PS; | H, A | Fair
| USA | 48% | | yes | 18 | PS to child only | | | -0.9 | p < 0.05, PS to parent and child vs. PS to child only
| | 4% | | yes | 45–60 min | No PS | | | -1.1
| | | | I + G | 810–1080 min
Epstein et al 2001 ^104^ | 67 families | 8–12 | 60.2% overweight (compared to the 50%ile BMI for age and sex); | BM, D,E | 6 mo | Increased PA | change in absolute BMI (statistical comparisons done on percent overweight change) | 12 months | girls: -0.27 kg/m^2^; | p < 0.01, interaction of group by sex; | none | Fair
| USA | 52% | BMI 27.4 kg/m^2^ (3.6 kg/m^2^) | yes | 20 | Combined increased PA + decreased SB | | | boys: -0.65 kg/m^2^ | p < 0.001, boys in combined group vs. girls in combined group
| | NR | | yes | 30 min | | | | girls: 1.0 kg/m^2^; boys: -1.76 kg/m^2^ | p < 0.05, boys in combined group vs. girls in increased PA group
| | | | I + G | 600 min
Flodmark et al 1993 ^105^ | 44 children (plus 50 matched controls) | 10–11 | 24.7 kg/m^2^ (family therapy group); | D,E | 14–18 mo | Family therapy | change in BMI (kg/m2) | 26 – 30 months | 1.1 kg/m^2^ | p < 0.05, family therapy vs. untreated controls | P | Fair
| Sweden | 48% | 25.5 kg/m^2^ (conventional treatment group); | no | 5 + 6 family therapy sessions | Conventional treatment | | | 1.6 kg/m^2^
| | NR (Swedish) | 25.1 kg/m^2^ (control group) | yes | NR | Matched controls - untreated | | | 2.8 kg/m^2^
| | | | I | NR
Golan et al 1998 ^106^ | 60 children | 6–11 | 39.1%overweight (conventional group); | BM,D,E | 1 yr | Conventional: children responsible for own wt loss | % overweight change | 12 months | -8.1% | p < 0.05 | none | Fair
| Israel | 38% | 39.6% (parents agents of change group) | yes | 30 | Parents exclusive agents of change | | | -14.7%
| | NR (Israeli) | | no* | 60 min
| | | | G+I | 1800 min
Graves et al 1988 ^107^ | 40 children | 6–12 | 52%–56% overweight | BM,D,E | 8 wk | BT + parent PS | % overweight change | 6 months | -24.5% | p < 0.05, PS vs BT only; | B | Fair
| USA | NR | | yes | 8 | BT only | | | -10.2% | p < 0.05, PS vs. instruction only
| | NR | | yes | 60 min | Instruction only | | | -9.5%
| | | | G | 480 min
Israel 1985 ^108^ | 33 children | 8–12 | 45.88% overweight (parent training group); | BM,D,E | 12 mo | BT + parent training in child management | % overweight change | 12 months | -10.2% | p < 0.001 | B | Fair-to-Poor
| USA | 30% | 53.13% (BT only); | yes | 17 | BT only | | | -1.3%
| | NR | 56.02% (controls) | yes | same +2–60 min sessions | Wait list controls | | | NR
| | | | G | >930 min
Israel et al 1994 ^109^ | 36 families | 8–13 | 48.1% overweight (enhanced child involvement group); | BM,D,E | 26 wk | Enhanced child involvement | % overweight change | 36 months | -4.8% | n.s. | none | Fair-to-Poor
| USA | NR | 46.0% (standard treatment group) | yes | 17 | Standard treatment (parents primarily responsible) | | | 6.4%
| | NR | | yes | 90 min
| | | | G | 1530 min
Kang et al 2002 ^111^ / Gutin et al 2002 ^110^ | 80 adolescents | 13–16 | 40.7% body fat (white boys); | BM,E | 8 mo | LSE + high intensity PA | change in % body fat | 8 months | -2.9% | n.s. | B, P | Fair-to-Poor
| USA | 33% | 45.8% body fat (white girls); | no | 160 | LSE + moderate PA | | | -1.4%
| | 69% | 43.9% body fat (black boys); | no | 60 min for LSE, variable for PA | LSE | | | -0.1%
| | | 45.2% body fat (black girls) | G | NR
Mellin et al 1987 ^112^ | 66 adolescents | 12–18 | 30–37% overweight | BM,D,E | 14 wk | SHAPEDOWN group (Cognitive, behavioral, affective treatment) | % overweight change | 15 months | -9.9% | Between group comparison NR | B, H | Fair
| USA | 21% | | yes | 16 | No treatment controls | | | -0.1% | (15 months vs. baseline: p < 0.01, SHAPEDOWN; n.s., control group)
| | 22% | | yes | 90 min
| | | | G | 1440 min
Saelens et al 2002 ^113^ | 44 adolescents | 12–16 | BMI 30.7 kg/m^2^ (3.1) | BM,D,E | 4 mo | Healthy habits intervention | % overweight change & change in BMI (statistical analyses on BMI z-scores) | 7 months | -2.4%, 0.1 kg/m2 | n.s. | B, A | Good
| USA | 59% | | yes | 13 | Typical care | | | 4.1%, 1.4 kg/m2
| | 30% | | no | 10–20 min for TC, NR for visit
| | | | I | NR, >200 min
Senediak and Spence 1985 ^114^ | 45 children | 6–13 approximately | 37.22% overweight | BM,D,E | 4 wk | Rapid schedule BT | % overweight change | 6 months | -14.7% | p < 0.05, rapid and gradual schedule BT groups combined vs. non-specific controls; | B | Fair-to-Poor
| USA | 66% | | yes | 8 | Gradually decreasing schedule BT | | | -18.3% | (comparison of rapid vs. gradual schedule BT groups n.s.)
| | NR | | yes | 90 min | Non-specific treatment controls | | | -10.9%
| | | | G | 720 min | Wait list controls | | | NR
Wadden et al 1990 ^115^ | 47 girls | 12–16 | 95.1 kg; | BM,D,E | 10 mo | Mother and child together | change in weight | 6 months | 1.7 kg | n.s. | P, H | Fair-to-Poor
| USA | 0% | BMI 35.6 kg/m^2^ | yes | 22 | Child alone | | | 3.0 kg
| | 100% black | | yes | 60 min (first 16 sessions), others NR | Mother and child separate | | | 3.5 kg
| | | | G | >960 min
White 2003 ^116^ / Williamson unpublished data | 57 adolescents | 11–15 | BMI 36.34 kg/m^2^; | BM,D,E | 6 mo | Behavioral | change in % body fat; change in BMI | 6 months | -1.12%; -0.19 kg/m2 | p < 0.05 (% body fat); | B | Good
| USA | 0% | 98.3 BMI %ile | yes | 4 + weekly website logins | Education only | | | 0.43%; 0.65 kg/m2 | P < 0.05 (change in BMI)
| | 100% | | yes | NR
| | | | I | NR

Intervention characteristics: BM=behavior modification; D = special diet; E = exercise program; G = group; I = individual;Other outcomes: B = behavioral ; P = physiological; H = childhood health outcomes; A = adverse effects

* for most intensive intervention which is listed first

** if multiple comparisons, then presented only if p < 0.05

Figure 4. Effects of behavioral weight loss treatment on BMI for children ages 8 to 13: Modeled results using CDC Growth Charts: United States. Body mass index-for-age percentiles: Girls, 2 to 20 years

Over half (n=13) of fair- or good-quality trials ^94,^ ^96^ – ^102,^ ^105,^ ^107,^ ^112,^ ^113,^ ^116^ reported intermediate behavioral (n=11) or physiologic (n=7) measures in addition to weight outcomes (Table 5). These outcomes were more common in recent research, and five of the six recent studies reported one or more. Two good-quality trials ^113,^ ^116^ reported behavioral changes but no physiological outcomes. While one of these trails ^116^ indicated reduced total daily energy intake in the active treatment group, neither indicated changes in physical activity. One fair-quality study reported reductions in targeted dietary components (fat or glycemic load of diet), but not kilocalories, ^96^ while other fair-quality studies ^97^ – ^102,^ ^107,^ ^112^ measuring changes in eating behaviors, physical activity, and sedentary behaviors did not provide a clear picture due to differences in subjects, interventions, and measures. No good-quality trials of behavioral treatment without pharmacologic adjuncts reported intermediate physiologic outcomes, such as lipids or lipoproteins, glucose tolerance, blood pressure, or physical fitness measures. Only one trial of at least fair quality reported key intermediate physiologic measures such as lipids or lipoproteins, glucose tolerance, or blood pressure. After an intensive six-month behavioral weight-control program comparing a reduced glycemic load (RGL) diet with a reduced fat (RF) diet, insulin resistance scores (measured by the homeostatic model) increased significantly less in the RGL group than the RF group (-0.4 +/- 0.9 vs. 2.6 +/- 1.2, p=0.03). ^96^ Insulin resistance, however, increases with sexual maturation, which was not assessed. The significance of these results is further limited given baseline differences between groups and lack of consideration of physical activity as a confounder. The other fair-quality studies measured other physiological outcomes such as physical work capacity or physical fitness and most reported some improvement when physical activity or sedentary behaviors were addressed in the intervention. ^97,^ ^98,^ ^101,^ ^102^

Considering all trials covered in the earlier review and this one (Table 5), no current trials addressed preschool children (two to five years of age). The majority of trials addressed children aged 6 to 12or 13 years (n = 15), with a growing number of studies addressing adolescents aged 11 or 12 years and older (n = 7). Studies generally include boys and girls, with some over-representation of females. Few studies clearly included 10% or more non-whites (n = 7), and many did not report participants' race/ethnicity (n = 12). Two studies included 100% black female adolescents, ^115,^ ^116^ but only one met at least fair quality criteria. ^116^

Comprehensive behavioral treatment programs have been the most studied intervention for overweight (Table 5). Fair- or good-quality studies have produced from 7% to 26% (generally 10%–20%) decreases in percent overweight (the most commonly reported outcome) from baseline after 12 to 24 months of intensive treatment. Much of this research has come from a single research group treating select patients aged 8–12 in a multidisciplinary obesity clinic setting specializing in behavioral therapy approaches to changing diet and activity behaviors. ^70^ Figure 4 models the BMI impacts of a 10%–20% reduction in overweight after 12 months in girls enrolled at ages 8–12. Methods for these calculations are described in Appendix P.

Long-term (after 5 to 10 years) weight outcomes from a set of these studies in 8–12 year olds in a multidisciplinary obesity clinic setting ^117^ generally maintained or improved weight-related treatment measures for the majority of patients. These studies are often cited, ^118,^ ^119^ but we excluded them from our review because most were prior to 1985, all involved intensive treatment-to-treatment comparisons without untreated controls, and we could not confirm the long-term results met our quality criteria (acceptable loss to follow-up of all those randomized, since analyses were not intention to treat). ^68^ Although this evidence offers hope of some success in treating childhood overweight for some subgroup of those treated, more generalizable and reliable evidence will be needed to accurately predict the probability of long-term treatment success in the broader population of overweight children and adolescents and to understand more about treatment responders.

Figure 5 demonstrates results from behavioral counseling studies in adolescents ^96,^ ^112,^ ^113,^ ^115,^ ^116^ with two good-quality studies particularly relevant to primary care. ^113,^ ^116^

Figure 5. Effects of behavioral weight loss treatment on BMI for adolescents using CDC Growth Charts: United States. Body mass index-for-age percentiles: Girls, 2 to 20 years

One short-term, primary care conducted trial used a computer-based approach to generate tailored plans for counseling of obese (above the adult BMI cutoff of 30) adolescents (aged 12 to 16) by trained and experienced pediatricians, supplemented with multiple follow-up telephone counseling calls from a qualified counselor. ^113^ Significant but small benefits were seen in BMI measures at seven months, primarily from stabilizing BMI (eliminating BMI increases) in those receiving the intensive intervention. While the magnitude of these benefits would be understated by this design, which compared two active treatments, changes were modest (Figure 5).

Similarly, a short-term trial that would be feasible for primary care involved an Internet- and e-mail-based family intervention targeting 57 overweight (mean BMI 36.37 kg/m ^2^ ) non-Hispanic black females aged 11 to 15 years with at least one obese biological parent. ^116^ Compared to a diet and physical activity education intervention, the comprehensive behavioral intervention resulted in a statistically significant difference in weight and BMI change from baseline between the two groups at six months, due largely to prevention of weight or BMI gain in the experimental group.

Although both trials showed small but statistically significant benefits in BMI measures at 6–12 months, it is not clear that these BMI changes would have clinical benefits or be sustained.

### Pharmacotherapy

One randomized placebo-controlled trial of sibutramine within a comprehensive behavioral treatment program in adolescents showed superior weight change outcomes after six months (4.6 kg greater weight loss, 95% CI 2.0–7.4 kg) in an intent-to-treat analysis ^94^ (Figure 5). With continued use, weight loss at six months was maintained through 12 months. The rate of adverse effects and discontinuation, however, was fairly high (12% discontinued and 28% reduced the medication). It is not clear that the additional short-term weight change provided a net benefit, since changes in serum lipids, serum insulin, serum glucose, and HOMA (homeostatic model of insulin sensitivity) did not differ between the groups. Among all trial completers (63%–76% of all participants) significant improvements from baseline were seen at 12 months in HDL cholesterol, serum insulin, and HOMA. Blood pressure was not improved, and in some cases, increased blood pressure was a reason for discontinuation. We found no evidence for the use of metformin for weight loss/disease prevention in normoglycemic obese adolescents with weight outcomes after more than three months, nor did we find acceptable evidence on alternative or complementary therapies.

### Surgery

No acceptable-quality evidence evaluated the effectiveness of surgical approaches to overweight in adolescents. There are no controlled treatment outcome data on bariatric surgery approaches in adolescents. Stringent NIH guidelines for surgery in the morbidly obese adolescent ^120^ specify strict qualification criteria and performance of surgery only in specialized centers with comprehensive weight-management programs. For mature, morbidly obese adolescents with comorbidities who meet these criteria, the evidence in adults ^121^ may be considered as a surrogate evidence source.

## Key Question 5. Do interventions lead to improved adult health outcomes, reduced childhood morbidity, and/or improved psychosocial and functional childhood outcomes?

### Behavioral Counseling Interventions

Few (n = 3) studies reported health outcomes as defined in our analytic framework, ^103,^ ^112,^ ^115^ and two of these were rated at least fair quality (Table 5). In one fair-quality trial, depression scores, measured using reliable and valid instruments, showed improvement from baseline in treated adolescent girls but not controls, while reliably measured self-esteem scores improved from baseline in both groups. ^112^ In a second fair-quality study, significantly fewer children aged 8–12 who received comprehensive behavioral treatment had elevated total behavior problem scores or elevated internalizing behavior problem scores at 24 months' follow-up than at baseline. ^103^

## Key Question 6. Do interventions have adverse effects, such as stigmatization, binging or purging behaviors, eating disorders, suppressed growth, or exercise-induced injuries?

Adverse effect reporting for behavioral counseling interventions was limited to 3 of 22 intervention trials.

### Behavioral Counseling Interventions

Potential eating problems or weight management behaviors were the only harms addressed in two trials. One good-quality trial reported no adverse effects on problematic eating (using validated measures for dietary restraint, eating disinhibition, problematic weight management behaviors, weight concerns, and eating disorder psychopathology) after primary care-based comprehensive behavioral treatment in 37 of 44 adolescent trial completers. ^113^ One fair-quality trial reported no effect on eating disorder symptoms, weight dissatisfaction, or purging/restricting behaviors in 47 8- to 12-year-olds in a family-based comprehensive behavioral treatment program, using a reliable measure (Kids' Eating Disorder Survey) that has been validated in slightly older children. ^103,^ ^122^ Differences between boys (no effect) and girls (elevated total scores) were not significant, but may be revealed in studies with larger sample sizes.

### Pharmacotherapy

In the placebo-controlled phase of the sibutramine trial, ^94^ 44% (19/43) of patients in the active medication group reduced or discontinued the medication due to elevated blood pressure, pulse rate, or both. These were the main adverse events reported.

### Surgery

We attempted to estimate the rate of harms from the uncontrolled cohort literature, but found loss to follow-up (25–60% at 4–24 months) ^123^ – ^125^ , and inadequate reporting prevented us from making reasonable estimates of rates of surgery-associated harms.

## Summary of Evidence Quality

Table 6 summarizes the overall quality of evidence according to USPSTF criteria ^68^ for each of the key questions addressed in this review. The overall evidence is poor for the direct effects of screening programs (KQ 1), screening harms (KQ 3), and bariatric surgery (KQs 4 and 5). The overall evidence is fair-to-poor for behavioral counseling interventions (KQs 4 and 5) due to small, non-comparable short-term studies with limited generalizability that rarely report health or intermediate outcomes, such as cardiovascular risk factors. Trials are particularly inadequate for non-whites and children aged 2–5. Fair-to-poor evidence is available for behavioral counseling intervention harms due to very limited reporting (KQ 6). Fair evidence supports childhood BMI as a risk factor for adult overweight, although data are again limited in non-whites (KQ 2b), and data addressing BMI as a risk factor for adult morbidities generally do not control for confounding by adult BMI (KQ 2c). Good evidence is available on the prevalence of overweight based on BMI measures in all groups except Native Americans and Asians (KQ 2a).

Table 6 Summary of Evidence Quality for Key Questions Addressing Childhood and Adolescent Overweight

Key Question | | Study Hierarchy | Overall USPSTF Quality
1. | Screening | - | Poor.
2a. | Prevalence | II-2 | Good, but lacking for specific non-white racial/ethnic subgroups.
2b,c. | Screening tests as a risk factor | II-2 | Fair. Data for BMI as a risk factor for adult overweight from childhood overweight are the most valid but are very limited for non-whites. Data for BMI as a risk factor for adult morbidities generally do not control for confounding by adult BMI.
3. | Screening harms | - | Poor. Due to lack of screening studies, possible harms can only be inferred from other sources.
4,5. | BCI | I | Fair-to-poor. Data are limited by very small samples, non-comparable interventions, & not using intent-to-treat analyses. Little reporting of intermediate outcomes—including risk factor changes, or changes in health outcomes. Poor generalizability due to specialist interventions not widely available and addressing mostly 8–12 years. No data in 2–5. Few trials include non-whites.
4,5. | Pharmacology with BCI | I | Fair. One good-quality trial in adolescents.
4,5. | Surgery | - | Poor.
6. | Intervention harms | I, II-2 | Fair-to-Poor. Very limited reporting of harms for BCI.