# Methods

## Terminology

Since BMI is the primary clinical measure and a measure of relative weight, we have adopted the use of the term “overweight” in children as opposed to obesity. ^10^ Considering the limitations of BMI in defining adiposity and concerns about labeling (stigma or concern resulting from being labeled “obese”), overweight is more accurate than obesity when designation in children is based on a BMI value alone. We adopt the term “overweight” to describe those with ≥ 95^th^ percentile BMI for age and sex and use “at risk for overweight” to describe those in the 85^th^ up to 95^th^ percentile for age and sex. ^8,^ ^9^

## Key Questions and Analytic Framework

Using the USPSTF's methods, ^68^ we developed an analytic framework (Figure 2) and seven key questions (KQs) to guide our literature search. The first KQ examined direct evidence that screening and intervention programs for overweight in children and adolescents improve age-appropriate behavioral, anthropometric, or physiologic measures. Because we found no evidence addressing this KQ, we searched for indirect evidence for KQs 2 through 6 to estimate the benefits and harms of screening and interventions for overweight. KQ 2 concerned appropriate standards for overweight in children and adolescents, the prevalence of overweight based on appropriate standards, and validity of clinical screening tests for overweight in predicting poorer health outcomes and obesity in adulthood. KQs 3 and 6 addressed adverse effects of screening and interventions for overweight, respectively. KQs 4 and 5 examined the efficacy of behavioral counseling, pharmacotherapeutic, and surgical interventions for improving age-appropriate anthropometric, physiologic, and health outcomes. The relationship between intervention-associated improvements in health measures and decreased morbidity in childhood or adulthood (KQ 7) was posited to be examined only in the presence of adequate evidence for intervention efficacy (KQs 4 and 5). We did not examine KQ 7 due to limited and inconsistent evidence for KQs 4 and 5.

Figure 2. Screening and interventions for overweight in childhood: Analytic framework and Key Questions

Review methods are further detailed in the appendixes.

## Literature Search Strategy

We developed literature search strategies and terms for each KQ (Appendix 4) and conducted four separate literature searches (for KQs 4, and 5; for KQs 1 and 2, for KQ 3; and for KQ 6) in Medline, PsycINFO, CINAHL, and the Cochrane library, to update the literature from previous good-quality systematic reviews (KQs 4, 5, and 6) through April 2004 or to comprehensively examine literature from 1966 to through April 2004 (KQs 1, 2, and 3). Literature searches were focused for each KQ as described, but were reviewed with all KQs in mind. Literature searches were extensively supplemented with outside source material from experts in the field and from examining the bibliographies of systematic and non-systematic reviews (Appendix E) and included trials. We also conducted limited hand searching of pediatric obesity-focused editions of selected journals. A single investigator reviewed abstracts, with all excluded abstracts reviewed by a second investigator for all KQs except KQ 2. Due to a very large yield of abstracts in this search, we conducted blinded dual review for a random subset (27%), with acceptable agreement (97.5%) between reviewers. Inter-reviewer discrepancies during the dual review process were resolved by consensus.

To address the time lag between completion of the evidence synthesis and publication, we repeated our literature search for KQs 4–6 for April 2004-2005, since these KQ represented the most critical evidence gaps identified through the systematic review. We reviewed 333 abstracts for KQs 4 and 5 and 91 abstracts for KQ 6 were reviewed. A total of 15 articles were pulled for further review. While two studies met inclusion criteria for KQ 4, none met inclusion criteria for KQ 5 or 6. Neither study changed the report findings and both were included in our listing of pending studies.

## Article Review and Data Abstraction

Using inclusion criteria developed for each key question as described in Appendix F, we reviewed 2,162 abstracts and 353 complete articles for KQ 1, 2,949 abstracts and 198 complete articles for KQs 4 and 5, and 1,176 abstracts and 36 complete articles for KQs 3 and 6. We included no articles for KQ 1, 41 articles for KQ 2, seven articles for KQ 3, 22 articles for KQs 4 and 5, and four articles for KQ 6. Listings of excluded articles are in Appendixes G and H. Two investigators quality rated all included articles and those excluded for quality reasons, using the USPSTF criteria (Appendix I).

For included studies, one primary reviewer abstracted relevant information into standardized evidence tables (Appendixes J, K, L, and M). To be within the USPSTF's scope, interventions needed to be primary care conducted or feasible (Appendix N), which were then categorized as pharmaceutical, surgical, or behavioral counseling interventions. Abstracted behavioral counseling intervention details included setting, type of professional delivering the intervention, parent/family participation, intervention components, number and type of contacts, and intervention duration. ^69^ Comprehensive behavioral treatments were those using a combination of behavioral modification (e.g., self-monitoring, stimulus control, cognitive-behavioral techniques), dietary modification (e.g., Traffic Light Diet, ^70^ reduced glycemic load, reduced fat or kilocalorie diets), and physical activity components (broadly specified as aerobic, calisthenic, lifestyle, or decreased sedentary behaviors) (Appendix O).

To be included, studies had to report weight outcomes, preferably as BMI or BMI percentile changes. We also recorded all reported behavioral, physiological, and health outcomes specified on our analytic framework (Figure 2).

## Literature Synthesis

There were insufficient homogeneous studies for any key question to allow quantitative synthesis. To better illustrate the study participants' degree of overweight and the impact of current clinical interventions on overweight, we converted baseline measures and outcomes to BMI percentiles and plotted results on Centers for Disease Control and Prevention (CDC) growth charts. Treatment effects that were typical of interventions in 8- to 12-year-olds (10%–20% reduction in percent overweight after one year) were modeled and plotted for 8-,10-, and 12-year-old girls. We plotted mean BMI treatment effects at six months or longer for all trials in adolescents for which this was possible. Methods are further described in Appendix P. Using a best evidence approach, we constructed a screening “outcomes” table to examine the proportion of adolescents with BMI ≥ 95^th^ percentile who would develop adult morbidities due to excess adult weight, and the proportion of morbidities potentially prevented by our estimates of reasonable effect sizes for adolescent intervention (Appendix Q). Using the USPSTF approach, we summarized the overall quality of the evidence for each key question.

## USPSTF Involvement

The authors worked intermittently with six liaisons from the USPSTF at key points throughout the review process to develop and refine the analytic framework and key questions and to present the evidence in a format that would be most useful to the USPSTF