# Appendix H. Exclusion Table for Key Questions 4 and 5

## References and Reason for Exclusion

Abu-Abeid S, Gavert N, Klausner JM, Szold A. Bariatric surgery in adolescence. Journal of Pediatric Surgery. 2003;38(9):1379-1382. Study design (case-series). [pmid: 14523824].
Allen GS. A double-blind clinical trial of diethylpropion hydrochloride, mazindol, and placebo in the treatment of exogenous obesity. Current Therapeutic Research. 1977;22:678-385. Mazindol study; published prior to 1985.
Andelman MB, Jones C, Nathan S. Treatment of obesity in underprivileged adolescents. Comparison of diethylpropion hydrochloride with placebo in a double-blind study. Clin Pediatr (Phila). 1967;6:327-330. Less than 6 mos f/u. [pmid: 5338123].
Anderson JW, Hamilton CC, Crown-Weber E, Riddlemoser M, Gustafson NJ. Safety and effectiveness of a multidisciplinary very-low-calorie diet program for selected obese individuals. J Am Diet Assoc. 1991;91:1582-1584. Peds data not reported separately; study design (case series). [pmid: 1960353].
Baird IM, Howard AN. A double-blind trial of mazindol using a very low calorie formula diet. International Journal of Obesity. 1977;1:271-278. Mazindol study; published prior to 1985. [pmid: 363631].
Bal' LV, Shugaeva EN, Deev AA, Maslova AR, Aleksandrov AA. Results of a three-year trial of arterial hypertension prevention in a population of children aged 11–15 years by overweight control. Cor et Vasa. 1990;32(6):448-456. Not in exclusively overweight population; not primary care feasible/referable. [pmid: 2085976].
Balagopal P, Bayne E, Sager B, Russell L, Patton N, George D. Effect of lifestyle changes on whole-body protein turnover in obese adolescents. International Journal of Obesity & Related Metabolic Disorders. 2003;27(10):1250-1257. Less than 6 mos f/u. [pmid: 14513074].
Barbeau P, Gutin B, Litaker M, Owens S, Riggs S, Okuyama T. Correlates of individual differences in body-composition changes resulting from physical training in obese children. Am J Clin Nutr. 1999;69(4):705-711. Less than 6 mos f/u. [pmid: 10197572].
Barbeau P, Litaker MS, Woods KF, Lemmon CR, Humphries MC, Owens S, et al. Hemostatic and inflammatory markers in obese youths: effects of exercise and adiposity. Journal of Pediatrics. 2002;141(3):415-420. Baseline and post-intervention weights are not reported. [pmid: 12219065].
Barbeau P, Gutin B, Litaker MS, Ramsey LT, Cannady WE, Allison J, et al. Influence of physical training on plasma leptin in obese youths. Canadian Journal of Applied Physiology. 2003;28(3):382-396. Baseline and post-intervention weights are not reported. [pmid: 12955866].
Barry H. Is a low-carbohydrate diet more effective in adolescents than a low-fat diet? Evidence-Based Practice 2003:6(7);11–2, 2p. Summary of Sondike, 2003 which is less than 6 mos f/u
Becque et al. Coronary risk incidence obese adolescents: reduction by exercise plus diet intervention. Pediatrics 1988: 81; 605–612. Less than 6 mos f/u
Black DR, Lantz CE. Spouse involvement and a possible long-term follow-up trap in weight loss. Behav Res Ther. 1984;22:557-562. Published prior to 1985. [pmid: 6508706].
Braet C, Van Winckel M, Van Leeuwen K. Follow-up results of different treatment programs for obese children. Acta Paediatr. 1997;86:397-402. CCT, not primary care feasible or referable. [pmid: 9174227].
Braet C, Tanghe A, Bode PD, Franckx H, Winckel MV. Inpatient treatment of obese children: a multicomponent programme without stringent calorie restriction. European Journal of Pediatrics. 2003;162(6):391-396. Not primary care referable. [pmid: 12756560].
Brandou F, Dumortier M, Garandeau P, Mercier J, Brun JF. Effects of a two-month rehabilitation program on substrate utilization during exercise in obese adolescents. Diabetes & Metabolism. 2003;29(1):20-27. Less than 6 mos f/u. [pmid: 12629444].
Brownell KD, Stunkard AJ. Couples training, pharmacotherapy and behavior therapy in the treatment of obesity. Arch Gen Psychiatry. 1981;38:1224-1229. Published prior to 1985. [pmid: 7305602].
Brownell KD, Kelman JH, Stunkard AJ. Treatment of obese children with and without their mothers: changes in weight and blood pressure. Pediatrics. 1983;71:515-523. Published prior to 1985. [pmid: 6835735].
Canty LM. Teen Obesity Addressed in the Military. Military Medicine. 2003;168(2):139-142. No controls. [pmid: 12636143].
Chen MY, Huang LH, Wang EK, Cheng NJ, Hsu CY, Hung LL, et al. The effectiveness of health promotion counseling for overweight adolescent nursing students in Taiwan. Public Health Nursing. 2001;18(5):350-356. Study design. [pmid: 11559418].
Christakis G, Sajecki S, Hillman RW, Miller E, Blumenthal S, Archer M. Effect of a combined nutrition education and physical fitness program on the weight status of obese high school boys. Fed.Proc. 1966;25:15-19. School-based; only 40% of pop is overweight. [pmid: 5006567].
Coney PJ WK. Weight change and adverse event incidence with a low-dose oral contraceptive: Two randomized, placebo-controlled trials. Contraception. 2001;63(6):297-302. Baseline and post-intervention weights are not reported. [pmid: 11672550].
Cuellar GE, et al. Six-month treatment of obesity with sibutramine 15 mg; a double-blind, placebo-controlled monocenter clinical trial in a Hispanic population. Obesity Research. 2000;8(1):71-82. Peds data not reported separately. [pmid: 10678261].
Davis BR, Blaufox MD, Oberman A, Wassertheil-Smoller S, Zimbaldi N, Cutler JA, Kirchner K, Langford HG. Reduction in long-term antihypertensive medication requirements. Effects of weight reduction by dietary intervention in overweight persons with mild hypertension. Arch Intern Med. 1993;153:1773-1782. Not a pediatric study (age 21–65 yrs). [pmid: 8333814].
Davis K, Christoffel KK. Obesity in preschool and school-age children. Treatment early and often may be best. Arch Pediatr Adolesc Med. 1994;148:1257-1261. Less than 6 mos f/u. [pmid: 7951803].
Denzer C, Reithofer E, Wabitsch M, Widhalm K. The outcome of childhood obesity management depends highly upon patient compliance. European Journal of Pediatrics. 2004;163(2):99-104. No untreated or comparison group. [pmid: 14691718].
DeWolfe JA, Jack E. Weight control in adolescent girls: a comparison of the effectiveness of three approaches to follow up. J Sch Health. 1984;54:347-349. School-based; published prior to 1985. [pmid: 6568354].
Dolan K, Creighton L, Hopkins G, Fielding G. Laparoscopic gastric banding in morbidly obese adolescents. Obes Surg. 2003;13(1):101-104. Study design (case-series). [pmid: 12630622].
Dubbert PM, Wilson GT. Goal-setting and spouse involvement in the treatment of obesity. Behav Res Ther. 1984;22:227-242. Published prior to 1985. [pmid: 6466273].
Ebbeling CB, Rodriguez NR. Effects of exercise combined with diet therapy on protein utilization in obese children. Med Sci Sports Exerc. 1999;31:378-385. Less than 6 mos f/u. [pmid: 10188741].
Ekelund U, Aman J, Yngve A, Renman C, Westerterp K, Sjostrom M. Physical activity but not energy expenditure is reduced in obese adolescents: a case-control study.[see comment]. American Journal of Clinical Nutrition. 2002;76(5):935-941. Study design; less than 6 mos f/u. [pmid: 12399263].
Eliakim A, Kaven G, Berger I, Friedland O, Wolach B, Nemet D. The effect of a combined intervention on body mass index and fitness in obese children and adolescents - a clinical experience. European Journal of Pediatrics. 2002;161(8):449-454. CCT. [pmid: 12172831].
Epstein LH, Wing RR, Koeske R, et al. Child and parent weight loss in family-based behavior modification programs. J Consult Clin Psychol. 1981;49:674-685. Published prior to 1985. [pmid: 7287977].
Epstein LH, Koeske R, Wing RR. Adherence to Exercise in Obese Children. Journal of Cardiac Rehabilitation. 1984;4:185-195. Published prior to 1985.
Epstein LH, Wing RR, Koeske R. Effects of diet plus exercise on weight change in parents and children. J Consult Clin Psychol. 1984;52:429-437. Published prior to 1985. [pmid: 6747061].
Epstein LH, Wing RR, Koeske R, Valoski A. Effect of parent weight on weight loss in obese children. J Consult Clin Psychol. 1986;54:400-401. Baseline and post-intervention weights are not reported. [pmid: 3722572].
Epstein LH, Wing RR, Valoski A, Gooding W. Long-term effects of parent weight on child weight loss. Behav Ther. 1987;18:219-226. Evaluates parent weight as prognostic factor; does not present baseline characteristics or attrition rates stratified by intervention group, therefore unable to assess USPSTF quality grade.
Estelles A, Dalmau J, Falco C, Berbel O, Castello R, Espana F, et al. Plasma PAI-1 levels in obese children—effect of weight loss and influence of PAI-1 promoter 4G/5G genotype. Thrombosis & Haemostasis. 2001;86(2):647-652. Study design; less than 6 mos f/u. [pmid: 11522017].
Faith MS, Berman N, Heo M, Pietrobelli A, Gallagher D, Epstein LH, et al. Effects of contingent television on physical activity and television viewing in obese children. Pediatrics. 2001;107(5):1043-1048. Less than 6 mos f/u. [pmid: 11331684].
Fanghanel G, Cortinas L, Sanchez-Reyes L, Berber A. A clinical trial of the use of sibutramine for the treatment of patients suffering essential obesity. International Journal of Obesity & Related Metabolic Disorders. 2000;24:144-150. Peds data not reported separately. [pmid: 10702763].
Fanghanel G, Cortinas L, Sanchez-Reyes L, Berber A. Second phase of a double-blind study clinical trial on Sibutramine for the treatment of patients suffering essential obesity: 6 months after treatment cross-over. International Journal of Obesity & Related Metabolic Disorders. 2001;25:741-747. Peds data not reported separately. [pmid: 11360159].
Favretti F, Cadiere GB, Segato G, Himpens J, De Luca M, Busetto L, De Marchi F, Foletto M, Caniato D, Lise M, Enzi G. Laparoscopic banding: selection and technique in 830 patients. Obesity Surgery. 2002;12:385-390. Peds data not separate. [pmid: 12082893].
Field AE, Austin SB, Taylor CB, Malspeis S, Rosner B, Rockett HR, et al. Relation between dieting and weight change among preadolescents and adolescents. Pediatrics. 2003;112(4):900-906. Intervention not administered by a professional. [pmid: 14523184].
Figueroa-Colon R, von Almen TK, Franklin FA, Schuftan C, Suskind RM. Comparison of two hypocaloric diets in obese children. American Journal of Diseases of Children. 1993;147:160-166. CCT. [pmid: 8427238].
Foster GD, Wadden TA, Brownell KD. Peer-led program for the treatment and prevention of obesity in the schools. J Consult Clin Psychol. 1985;53:538-540. Less than 6 mos f/u. [pmid: 4031211].
Gately PJ, Cooke CB, Butterly RJ, Mackreth P, Carroll S. The effects of a children's summer camp programme on weight loss, with a 10 month follow-up. International Journal of Obesity & Related Metabolic Disorders. 2000;24(11):1445-1452. Study design (case-series). [pmid: 11126341].
Gehrman CA, Effects of a physical activity and nutrition intervention on body image in pre-adolescents. Dissertation Abstracts International: Section B: the Sciences & Engineering 2003:Vol 64(3-B). Not in overwt or at risk for overwt population
Gortmaker SL, Peterson K, Wiecha J, Sobol AM, Dixit S, Fox MK, Laird N. Reducing obesity via a school-based interdisciplinary intervention among youth: Planet Health. Archives of Pediatrics & Adolescent Medicine. 1999;153:409-418. Not primary care-feasible or referable (school-based). [pmid: 10201726].
Grignard S, Jean-Pierre B, Michel B, Philippe M, Chantal V. Characteristics of adolescent attempts to manage overweight. Patient Education & Counseling. 2003;51(2):183-189. Study design. [pmid: 14572949].
Gutin B, Cucuzzo N, Islam S, Smith C, Stachura ME. Physical training, lifestyle education, and coronary risk factors in obese girls. Medicine & Science in Sports & Exercise. 1996;28(1):19-23. Less than 6 mos f/u. [pmid: 8775350].
Gutin B, Owens S, Okuyama T, Riggs S, Ferguson M, Litaker M. Effect of physical training and its cessation on percent fat and bone density of children with obesity. Obesity Research. 1999;7(2):208-214. Less than 6 mos f/u. [pmid: 10102258].
Hamilton JL, James FW, Bazargan M. Provider practice, overweight and associated risk variables among children from a multi-ethnic underserved community. J Natl Med Assoc. 2003;95(6):441-448. Not a CCT/RCT. [pmid: 12856909]. [pmcid: 2594548].
Herrera EA, Johnston CA, Steele RG. A comparison of cognitive and behavioral treatments for pediatric obesity. Children's Health Care. 2004;33(2):151-167. Less than 6 mos f/u.
Hills AP, Parker AW. Obesity management via diet and exercise intervention. Child Care Health. 1988;14:409-416. Less than 6 mos f/u.
Hipsky J, Kirk S. HealthWorks! Weight management program for children and adolescents. Journal of the American Dietetic Association. 2002;102(3S):S64-S67. Study design. [pmid: 11902390].
Hoerr SL, Nelson RA, Essex-Sorlie D. Treatment and follow-up of obesity in adolescent girls. Journal of Adolescent Health Care. 1988;9(1):28-37. No controls. [pmid: 3335468].
Hoffman RP, Stumbo PJ, Janz KF, Nielsen DH. Altered insulin resistance is associated with increased dietary weight loss in obese children. Horm Res. 1995;44(1):17-22. Less than 6 mos f/u. [pmid: 7649522].
Hoie LH, Bruusgaard D. Compliance, clinical effects, and factors predicting weight reduction during a very low calorie diet regime. Scand J Prim Health Care. 1995;13:13-20. Less than 6 mos f/u; peds data not reported separately. [pmid: 7777729].
Hoos MB, Gerver WJ, Kester AD, Westerterp KR. Physical activity levels in children and adolescents. International Journal of Obesity & Related Metabolic Disorders. 2003;27(5):605-609. No wt loss intervention tested. [pmid: 12704404].
Inge TH, Garcia V, Daniels S, Langford L, Kirk S, Roehrig H, Amin R, Zeller M, Higa K. A multidisciplinary approach to the adolescent bariatric surgical patient. Journal of Pediatric Surgery. 2004;39(3):442-7. Study design (case-series). [pmid: 15017567].
Israel AC, Saccone AJ. Follow-up of effects of choice of mediator and target of reinforcement on weight loss. Behav Ther. 1979;10:260-265. Published prior to 1985.
James WP, Astrup A, Finer N, Hilsted J, Kopelman P, Rossner S, Saris WH, Van Gaal LF. Effect of sibutramine on weight maintenance after weight loss: a randomised trial. STORM Study Group. Sibutramine Trial of Obesity Reduction and Maintenance. Lancet. 2000;356:2119-2125. Peds data not reported separately. [pmid: 11191537].
Jiao et al. Clinical study on rhubarb extract tablet in treating simple obesity. CJIM 2001: 7(1); 33–35. Less than 6 mos f/u
Johnson WG, Hinkle LK, Carr RE, et al. Dietary and exercise interventions for juvenile obesity: long-term effects of behavioural and public health models. Obs Res. 1997;5:257-61. Poor USPSTF Quality grade.
Karvetti RL, Hakala P. A seven-year follow-up of a weight reduction programme in Finnish primary health care. Eur J Clin Nutr. 1992;46:743-752. Peds data not reported separately. [pmid: 1425528].
Kay JP, Alemzadeh R, Langley G, D'Angelo L, Smith P, Holshouser S. Beneficial effects of metformin in normoglycemic morbidly obese adolescents. Metabolism: Clinical & Experimental. 2001;50(12):1457-1461. Less than 6 mos f/u; disease-specific patient population: hyperinsulinemic, non-diabetic obese adolescents. [pmid: 11735093].
Kirschenbaum DS, Harris ES, Tomarken AJ. Effects of parental involvement in behavioral weight loss therapy for preadolescents. Behav Ther. 1984;15:485-500. Published prior to 1985.
Levine MD, Ringham RM, Kalarchian MA, Wisniewski L, Marcus MD. Is family-based behavioral weight control appropriate for severe pediatric obesity?. International Journal of Eating Disorders. 2001;30(3):318-328. Less than 6 mos f/u; no control group. [pmid: 11746293].
Lorber J. Obesity in childhood. A controlled trial of anorectic drugs. Arch Dis Child. 1966;41:309-312. Less than 6 mos f/u. [pmid: 5328625]. [pmcid: 2019558].
Luepker RV, Perry CL, McKinlay SM, Nader PR, Parcel GS, Stone EJ, Webber LS, Elder JP, Feldman HA, Johnson CC. Outcomes of a field trial to improve children's dietary patterns and physical activity. The Child and Adolescent Trial for Cardiovascular Health. CATCH collaborative group. JAMA. 1996;275:768-776. Not primary care-feasible or referable (school-based). [pmid: 8598593].
Maclay WP, Wallace MG. A multi-centre general practice trial of mazindol in the treatment of obesity. Practitioner. 1977;218:431-434. Mazindol study; published prior to 1985. [pmid: 322112].
Manios Y, Moschandreas J, Hatzis C, Kafatos A. Evaluation of a health and nutrition education program in primary school children of Crete over a three-year period. Prev Med. 1999;28:149-159. Not primary care-feasible or referable (school-based). [pmid: 10048106].
Manning RM, Jung RT, Leese GP, Newton RW. The comparison of four weight reduction strategies aimed at overweight diabetic patients. Diabet Med. 1995;12:409-415. All diabetic patients. [pmid: 7648803].
McCann S, McDuffie J, Nicholson J, Sastry L, Calis K, Yanovski J. A pilot study of the efficacy of orlistat in overweight adolescents. Obes.Res. 2000;8(S1):58S. Less than 6 mos f/u; no controls.
McDuffie JR, Calis KA, Uwaifo GI, Sebring NG, Fallon EM, Frazer TE, et al. Efficacy of orlistat as an adjunct to behavioral treatment in overweight African American and Caucasian adolescents with obesity-related co-morbid conditions. Journal of Pediatric Endocrinology. 2004;17(3):307-319. Study design (case series); also required to have obesity-related comorbid condition.
Miller K, Hell E. Laparoscopic adjustable gastric banding: a prospective 4-year follow-up study. Obesity Surgery. 1999;9(2):183-187. Study design (case series); results for pediatric age group not reported separately. [pmid: 10340775].
Mirouze J, Mary P, Schmouker Y, Lapinski H, Chauchard C, Prunac N. [Alternating low calory diets (200 to 1000 calories), their value in the treatment of resistant obesity]. Sem.Hop. 1976;52:2255-2261. Published prior to 1985. [pmid: 188176].
Molnar D, Torok K, Erhardt E, Jeges S. Safety and efficacy of treatment with an ephedrine/caffeine mixture. The first double-blind placebo-controlled pilot study in adolescents. International Journal of Obesity & Related Metabolic Disorders. 2000;24(12):1573-1578. Less than 6 mos f/u. [pmid: 11126208].
Molokhia M. Obesity wars: a pilot study of very low calorie diets in obese patients in general practice. Br J Gen Pract. 1998;48:1251-1252. Not a pediatric study (age 27–83 yrs). [pmid: 9692287]. [pmcid: 1410173].
Moon YI, Park HR, Koo HY, Kim HS. Effects of behavior modification on body image, depression and body fat in obese Korean elementary school children. Yonsei Medical Journal. 2004;45(1):61-67. CCT. [pmid: 15004870].
Murphy JK. The long-term effects of spouse involvement upon weight loss and maintenance. Behav Ther. 1982;13:681-693. Published prior to 1985.
Norgren S, Danielsson P, Jurold R, Lotborn M, Marcus C. Orlistat treatment in obese prepubertal children: a pilot study. Acta Paediatrica. 2003;92(6):666-670. Less than 6 mos f/u; no controls. [pmid: 12856974].
Nova A, Russo A, Sala E. Long-term management of obesity in paediatric office practice: experimental evaluation of two different types of intervention. Ambul Child Health. 2001;7:239-47. Poor USPSTF Quality grade.
Nuutinen O. Long-term effects of dietary counselling on nutrient intake and weight loss in obese children. European Journal of Clinical Nutrition. 1991;45(6):287-297. CCT, inappropriate control group. [pmid: 1915202].
Nuutinen O, Knip M. Predictors of weight reduction in obese children. European Journal of Clinical Nutrition. 1992;46(11):785-794. No wt loss intervention tested. [pmid: 1425532].
Obarzanek E, Hunsberger SA, Van Horn L, Hartmuller VV, Barton BA, Stevens VJ, Kwiterovich PO, Franklin FA, Kimm SY, Lasser NL, Simons-Morton DG, Lauer RM. Safety of a fat-reduced diet: the Dietary Intervention Study in Children (DISC). Pediatrics. 1997;100:51-59. All children with high LDL. [pmid: 9200359].
Owens S, Gutin B, Allison J, et al. Effect of physical training on total and visceral fat in obese children. Med Sci Sports Exerc. 1999;31:143-148. Less than 6 mos f/u. [pmid: 9927022].
Pearce JW, LeBow MD, Orchard J. Role of spouse involvement in the behavioral treatment of overweight women. J Consult Clin Psychol. 1981;49:236-244. Published prior to 1985. [pmid: 7217490].
Pidlich J, Pfeffel F, Zwiauer K, Schneider B, Schmidinger H. The effect of weight reduction on the surface electrocardiogram: a prospective trial in obese children and adolescents. Int J Obes Relat Metab Disord. 1997;21:1018-1023. Less than 6 mos f/u. [pmid: 9368825].
Pittler MH. Rhubarb extract — helpful in treating obesity?. Focus on Alternative & Complementary Therapies. 2001;6(3):195-6. Summary of Jiao et al 2001, which is less than 6 mos f/u.
Raeburn JM, Atkinson JM. A low-cost community approach to weight control: initial results from an evaluated trial. Prev Med. 1986;15:391-402. Peds data not reported separately. [pmid: 3763562].
Randolph JG, Weintraub WH, Rigg A. Jejunoileal bypass for morbid obesity in adolescents. J Pediatr Surg. 1974;9:341-345. Study design (case-series); jejunoileal bypass surgery. [pmid: 4843988].
Reinehr T, Kersting M, Alexy U, Andler W. Long-term follow-up of overweight children: after training, after a single consultation session, and without treatment. Journal of Pediatric Gastroenterology & Nutrition. 2003;37(1):72-74. CCT. [pmid: 12827009].
Reiterer EE, Sudi KM, Mayer A, Limbert-Zinterl C, Stalzer-Brunner C, Fuger G, et al. Changes in leptin, insulin and body composition in obese children during a weight reduction program. Journal of Pediatric Endocrinology & Metabolism. 1999;12(6):853-862. Less than 6 mos f/u; no controls. [pmid: 10614543].
Rigg CA: Proceedings: Jejunoileal bypass by morbidly obese adolescent. Acta Paediatr Scand Suppl 1975:62–64 Jejunoileal bypass surgery; published prior to 1985
Robinson TN. Behavioural treatment of childhood and adolescent obesity. International Journal of Obesity & Related Metabolic Disorders. 1999;23(S22):S52-7. Not primary care-feasible or referable (school-based). [pmid: 10340806].
Rocchini AP, Katch V, Anderson J, Hinderliter J, Becque D, Martin M, Markes C. Blood pressure in obese adolescents: effect of weight loss. Pediatrics. 1988;82:16-23. Less than 6 mos f/u. [pmid: 3288957].
Rolland-Cachera MF, Thibault H, Souberbielle JC, Soulie D, Carbonel P, Deheeger M, Roinsol D, Longueville E, Bellisle F, Serog P. Massive obesity in adolescents: dietary interventions and behaviours associated with weight regain at 2 y follow-up. International Journal of Obesity. 2004;28:514-519. Not primary care-feasible. [pmid: 14968129].
Rosenthal B, Allen GJ, Winter C. Husband involvement in the behavioral treatment of overweight women: initial effects and long-term follow-up. Int J Obes Relat Metab Disord. 1980;4:165-173. Published prior to 1985.
Saccone AJ, Israel AC. Effects of experimenter versus significant other-controlled reinforcement and choice of target behavior on weight loss. Behav Ther. 1978;9:271-278. Published prior to 1985.
Sartorio A, Lafortuna CL, Marinone PG, Tavani A, La Vecchia C, Bosetti C. Short-term effects of two integrated, non-pharmacological body weight reduction programs on coronary heart disease risk factors in young obese patients. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2003;16(4):262-265. Not a pediatric study.
Savage MP, Petratis MM, Thomson WH, Berg K, Smith JL, Sady SP. Exercise training effects on serum lipids of prepubescent boys and adult men. Med Sci Sports Exerc. 1986;18(2):197-204. Less than 6 mos f/u. [pmid: 3702647].
Schwingshandl J, Sudi K, Eibl B, Wallner S, Brokenstein M. Effect of an individualised training programme during weight reduction on body composition: a randomised trial. Arch Dis Child. 1999;81:426-428. Less than 6 mos f/u. [pmid: 10519718]. [pmcid: 1718135].
Sondike SB, Copperman N, Jacobson MS. Effects of a low-carbohydrate diet on weight loss and cardiovascular risk factor in overweight adolescents. Journal of Pediatrics. 2003;142(3):253-258. Less than 6 mos f/u. [pmid: 12640371].
Sothern, Udall JN, Jr., Suskind RM, Vargas A, Blecker U: Weight loss and growth velocity in obese children after very low calorie diet, exercise, and behavior modification. Acta Paediatrica. 2000: 89;1036–1043 Study design (case-series)
Spieth LE, Harnish JD, Lenders CM, Raezer LB, Pereira MA, Hangen SJ, Ludwig DS. A low-glycemic index diet in the treatment of pediatric obesity. Archives of Pediatrics & Adolescent Medicine. 2000;154:947-951. Less than 6 mos f/u. [pmid: 10980801].
Stallings VA, Archibald EH, Pencharz PB. Potassium, magnesium, and calcium balance in obese adolescents on a protein-sparing modified fast. Am J Clin Nutr. 1988;47(2):220-224. Less than 6 mos f/u; not primary care-feasible or referable (inpatient hospital setting). [pmid: 3341251].
Stanford A, Glascock JM, Eid GM, Kane T, Ford HR, Ikramuddin S, Schauer P. Laparoscopic Roux-en-Y gastric bypass in morbidly obese adolescents. Journal of Pediatric Surgery. 2003;38(3):430-433. Study design. [pmid: 12632362].
Strauss RS, Bradley LJ, Brolin RE. Gastric bypass surgery in adolescents with morbid obesity. J Pediatr. 2001;138:499-504. Study design (case-series). [pmid: 11295712].
Sugerman HJ, Sugerman EL, DeMaria EJ, Kellum JM, Kennedy C, Mowery Y, et al. Bariatric surgery for severely obese adolescents. Journal of Gastrointestinal Surgery. 2003;7(1):102-107. Study design (case-series). [pmid: 12559191].
Sung RY, Yu CW, Chang SK, Mo SW, Woo KS, Lam CW. Effects of dietary intervention and strength training on blood lipid level in obese children. Archives of Disease in Childhood. 2002;86(6):407-410. Less than 6 mos f/u. [pmid: 12023168]. [pmcid: 1763008].
Suskind R, Blecker U, Udall J Jr, Von Almen T, Schumacher H, Carlisle L, Sothern M. Recent advances in the treatment of childhood obesity. Pediatric Diabetes. 2000;1(1):23-33. Study design. [pmid: 15016239].
Suttapreyasri D, Suthontan N, Kanpoem J, Krainam J, Boonsuya C. Weight-control training-models for obese pupils in Bangkok. Journal of the Medical Association of Thailand. 1990;73(7):394-400. Not primary care-feasible or referable (school-based). [pmid: 2246627].
Talvia S, Lagstrom H, Rasanen M, Salminen M, Rasanen L, Salo P, Viikari J, Ronnemaa T, Jokinen E, Vahlberg T, Simell O. A randomized intervention since infancy to reduce intake of saturated fat: calorie (energy) and nutrient intakes up to the age of 10 years in the Special Turku Coronary Risk Factor Intervention Project. Arch Pediatr Adolesc Med. 2004;158(1):41-47. Not in an overweight population; baseline & post-intervention weight not measured. [pmid: 14706957].
Tershakovec AM, Jawad AF, Stallings VA, Zemel BS, McKenzie JM, Stolley PD, Shannon BM. Growth of hypercholesterolemic children completing physician-initiated low-fat dietary intervention. J Pediatr. 1998;133:28-34. All patients had high cholesterol. [pmid: 9672506].
Tounian P, Frelut ML, Parlier G, Abounaufal C, Aymard N, Veinberg F, Fontaine JL, Girardet JP. Weight loss and changes in energy metabolism in massively obese adolescents. Int J Obes Relat Metab Disord. 1999;23:830-837. Less than 6 mos f/u. [pmid: 10490784].
Treuth MS, Sunehag AL, Trautwein LM, Bier DM, Haymond MW, Butte NF. Metabolic adaptation to high-fat and high-carbohydrate diets in children and adolescents. American Journal of Clinical Nutrition. 2003;77(2):479-489. Intervention not tested in overweight or at-risk for overweight population. [pmid: 12540411].
Valverde MA, Patin RV, Oliveira FL, Lopez FA, Vitolo MR. Outcomes of obese children and adolescents enrolled in a multidisciplinary health program. International Journal of Obesity & Related Metabolic Disorders. 1998;22(6):513-519. No controls. [pmid: 9665671].
Vandenplas Y, Bollen P, De Langhe K, Vandemaele K, De Schepper J. Intragastric balloons in adolescents with morbid obesity. European Journal of Gastroenterology & Hepatology. 1999;11(3):243-245. No controls. [pmid: 10333195].
Vandongen R, Jenner DA, Thompson C, Taggart AC, Spickett EE, Burke V, Beilin LJ, Milligan RA, Dunbar DL. A controlled evaluation of a fitness and nutrition intervention program on cardiovascular health in 10- to 12-year-old children. Prev Med. 1995;24:9-22. Not primary care-feasible or referable (school-based). [pmid: 7740021].
Vogiatzi MG, Boeck MA, Vlachopapadopoulou E, el Rashid R, New MI. Dehydroepiandrosterone in morbidly obese adolescents: effects on weight, body composition, lipids, and insulin resistance. Metabolism: Clinical & Experimental. 1996;45(8):1011-1015. Less than 6 mos f/u. [pmid: 8769361].
Wabitsch M, Hauner H, Heinze E, Bockmann A, Benz R, Mayer H, Teller W. Body fat distribution and steroid hormone concentrations in obese adolescent girls before and after weight reduction. Journal of Clinical Endocrinology & Metabolism. 1995;80(12):3469-3475. Less than 6 mos f/u. [pmid: 8530585].
Wabitsch M, Braun U, Heinze E, Muche R, Mayer H, Teller W, et al. Body composition in 5–18-y-old obese children and adolescents before and after weight reduction as assessed by deuterium dilution and bioelectrical impedance analysis. American Journal of Clinical Nutrition. 1996;64(1):1-6. Less than 6 mos f/u. [pmid: 8669403].
Wallace AG. AN 448 Sandoz (Mazindol) in the treatment of obesity. Med J Aust. 1976;1:343-345. Mazindol study; published prior to 1985. [pmid: 775265].
Warschburger P, Fromme C, Petermann F, Wojtalla N, Oepen J. Conceptualisation and evaluation of a cognitive-behavioural training programme for children and adolescents with obesity. International Journal of Obesity & Related Metabolic Disorders. 2001;25(Suppl 1):S93-S95. Poor USPSTF Quality grade; not primary care feasible or referable. [pmid: 11466598].
White JJ, Cheek D, Haller JA Jr. Small bowel bypass is applicable for adolescents with morbid obesity. American Surgeon. 1974;40:704-708. Study design (case-series). [pmid: 4429281].
Wilmore JH, Despres JP, Stanforth PR, Mandel S, Rice T, Gagnon J, et al. Alterations in body weight and composition consequent to 20 wk of endurance training: the HERITAGE Family Study. American Journal of Clinical Nutrition. 1999;70(3):346-352. Less than 6 mos f/u. [pmid: 10479196].
Wing RR, Marcus MD, Epstein LH, Jawad A. A “family-based” approach to the treatment of obese Type II diabetic patients. J Consult Clin Psychol. 1991;59:156-162. Study in adults only; population with specific disease (type II DM). [pmid: 2002132].
Wong ML, Koh D, Lee MH, Fong YT. Two-year follow-up of a behavioural weight control programme for adolescents in Singapore: predictors of long-term weight loss. Annals of the Academy of Medicine, Singapore. 1997;26(2):147-153. Peds data not reported separately; no controls who did not receive intervention.
Ylitalo VM. Treatment of obese schoolchildren. Klin Padiatr. 1982;194:310-314. CCT. [pmid: 7144047].
Yoshinaga M, Sameshima K, Miyata K, Hashiguchi J, Imamura M. Prevention of mildly overweight children from development of more overweight condition. Preventive Medicine. 2004;38(2):172-174. CCT. [pmid: 14715208].
Zhi J, Moore R, Kanitra L. The effect of short-term (21-day) orlistat treatment on the physiologic balance of six selected macrominerals and microminerals in obese adolescents. Journal of the American College of Nutrition. 2003;22(5):357-62. Less than 6 mos f/u. [pmid: 14559927].