# Appendix G. Exclusion Table for Key Questions 2b and 2c

## References and Reason for Exclusion

Abraham S, Nordsieck M. Relationship of excess weight in children and adults. Public Health Rep. 1960;75:263-73. Unusable reference standard. [pmid: 13791533].
Abraham S, Collins G, Nordsieck M. Relationship of childhood weight status to morbidity in adults. HSMHA Health Rep. 1971;86(3):273-284. Unusable reference standard Poor quality rating. [pmid: 5547793]. [pmcid: 1937073].
Abrantes MM, Lamounier JA, Colosimo EA. Comparison of body mass index values proposed by Cole et al. (2000) and Must et al. (1991) for identifying obese children with weight-for-height index recommended by the World Health Organization. Public Health Nutrition. 2003;6(3):307-311. Non-US population. [pmid: 12740080].
Allison DB, Zannolli R, Faith MS, Heo M, Pietrobelli A, VanItallie TB, Pi-Sunyer FX, Heymsfield SB. Weight loss increases and fat loss decreases all-cause mortality rate: results from two independent cohort studies. International Journal of Obesity & Related Metabolic Disorders. 1999;23(6):603-611. Wrong age group. [pmid: 10411233].
Aristimuno GG, Foster TA, Voors AW, Srinivasan SR, Berenson GS. Influence of persistent obesity in children on cardiovascular risk factors: the Bogalusa Heart Study. Circulation. 1984;69(5):895-904. Wrong age group Not an outcome of interest. [pmid: 6705165].
Arslanian S. Insulin secretion and sensitivity in healthy African-American vs American white children. Clin Pediatr(Phila). 1998;37(2):81-88. Not a longitudinal study Not an outcome of interest Wrong measure of OW. [pmid: 9492115].
Arslanian S. Type 2 diabetes in children: clinical aspects and risk factors. Hormone Research. 2002;57(Suppl 1):19-28. Not a longitudinal study. [pmid: 11979018].
Bao W, Srinivasan S, Valdez R, Greenlund K, Wattigney WA, Berenson GS. Longitudinal changes in cardiovascular risk from childhood to young adulthood in offspring of parents with coronary artery disease: the Bogalusa Heart Study.[comment]. JAMA. 1997;278(21):1749-1754. Wrong measure of OW. [pmid: 9388151].
Bao W, Srinivasan SR, Wattigney WA, Berenson GS. Persistence of multiple cardiovascular risk clustering related to syndrome X from childhood to young adulthood. The Bogalusa Heart Study. Arch Intern Med. 1994;154(16):1842-1847. Poor data on obesity tracking Wrong age group. [pmid: 8053753].
Bao W, Srinivasan SR, Berenson GS. Persistent elevation of plasma insulin levels is associated with increased cardiovascular risk in children and young adults. The Bogalusa Heart Study. Circulation. 1996;93(1):54-59. No report of childhood weight. [pmid: 8616941].
Barlow SE, Dietz WH. Obesity evaluation and treatment: Expert Committee recommendations. The Maternal and Child Health Bureau, Health Resources and Services Administration and the Department of Health and Human Services. Pediatrics. 1998;102(3):E29. Not a longitudinal study. [pmid: 9724677].
Barnekow-Bergkvist M, Hedberg G, Janlert U, Jansson E. Adolescent determinants of cardiovascular risk factors in adult men and women. Scandinavian Journal of Public Health. 2001;29(3):208-217. Non-US population. [pmid: 11680773].
Belamarich PF, Luder E, Kattan M, Mitchell H, Islam S, Lynn H, Crain EF. Do obese inner-city children with asthma have more symptoms than nonobese children with asthma?. Pediatrics. 2000;106(6):1436-1441. Not a longitudinal study. [pmid: 11099600].
Berenson GS, Wattigney WA, Tracy RE, Newman WP III, Srinivasan SR, Webber LS, Dalferes ER Jr, Strong JP. Atherosclerosis of the aorta and coronary arteries and cardiovascular risk factors in persons aged 6 to 30 years and studied at necropsy (The Bogalusa Heart Study). Am J Cardiol. 1992;70(9):851-858. Age at BMI measurement not reported. [pmid: 1529936].
Berenson GS, Srinivasan SR, Bao W, Newman WP 3rd, Tracy RE, Wattigney WA. Association between multiple cardiovascular risk factors and atherosclerosis in children and young adults. The Bogalusa Heart Study. N Engl J Med. Jun 4. 1998;338(23):1650-1656. Age at BMI measurement not reported. [pmid: 9614255].
Bhargava SK, Sachdev HS, Fall CH, Osmond C, Lakshmy R, Barker DJ, Biswas SK, Ramji S, Prabhakaran D, Reddy KS. Relation of serial changes in childhood body-mass index to impaired glucose tolerance in young adulthood. New England Journal of Medicine. 2004;350(9):865-875. Non-US population. [pmid: 14985484].
Biro FM, Lucky AW, Simbartl LA, Barton BA, Daniels SR, Striegel-Moore R, Kronsberg SS, Morrison JA. Pubertal maturation in girls and the relationship to anthropometric changes: pathways through puberty. Journal of Pediatrics. 2003;142(6):643-646. Wrong measure of OW. [pmid: 12838192].
Blackett PR, Taylor T, Russell D, Lu M, Fesmire J, Lee ET. Lipoprotein changes in relation to body mass index in Native American adolescents. Pediatric Research. 1996;40(1):77-81. Not a longitudinal study. [pmid: 8798250].
Bognetti E, Macellaro P, Novelli D, Meschi F, Ciralli F, Chiumello G. Prevalence and correlates of obesity in insulin dependent diabetic patients. Archives of Disease in Childhood. 1995;73(3):239-242. Non-US population. [pmid: 7492163]. [pmcid: 1511289].
Boxer GH, Bauer AM, Miller BD. Obesity-hypoventilation in childhood. J Am Acad Child Adolesc Psychiatry. 1988;27(5):552-558. Not a longitudinal study Limited to a specific disease. [pmid: 3182617].
Braddon FE, Rodgers B, Wadsworth ME, Davies JM. Onset of obesity in a 36 year birth cohort study. Br Med J (Clin Res Ed). 1986;293(6542):299-303. Non-US population.
Bray GA. Overweight is risking fate. Definition, classification, prevalence, and risks. Ann N Y Acad Sci. 1987;499:14-28. Not a longitudinal study. [pmid: 3300479].
Briend A, Zimicki S. Validation of arm circumference as an indicator of risk of death in one to four year old children. Nutrition Research. 1986;6:249-261. Non-US population.
Bringer J, Lefebvre P, Boulet F, Grigorescu F, Renard E, Hedon B, et al. Body composition and regional fat distribution in polycystic ovarian syndrome. Relationship to hormonal and metabolic profiles. Ann N Y Acad Sci. 1993;687:115-123. Non-US population. [pmid: 8323166].
Brinton LA, Swanson CA. Height and weight at various ages and risk of breast cancer. Annals of Epidemiology. 1992;2(5):597-609. Wrong measure of OW. [pmid: 1342311].
Britz B, Siegfried W, Ziegler A, Lamertz C, Herpertz-Dahlmann BM, Remschmidt H, et al. Rates of psychiatric disorders in a clinical study group of adolescents with extreme obesity and in obese adolescents ascertained via a population based study. International Journal of Obesity & Related Metabolic Disorders. 2000;24(12):1707-1714. Non-US population. [pmid: 11126229].
Burns TL, Moll PP, Lauer RM. The relation between ponderosity and coronary risk factors in children and their relatives. The Muscatine Ponderosity Family Study. American Journal of Epidemiology. 1989;129(5):973-987. Wrong measure of OW. [pmid: 2495713].
Byrnes SE, Baur LA, Bermingham M, Brock K, Steinbeck K. Leptin and total cholesterol are predictors of weight gain in pre-pubertal children. International Journal of Obesity & Related Metabolic Disorders. 1999;23(2):146-150. Non-US population. [pmid: 10078848].
Campbell K, Waters E, O'Meara S, Summerbell C. Interventions for preventing obesity in childhood. A systematic review. Obesity Reviews. 2001;2(3):149-157. Non-US population. [pmid: 12120100].
Caprio S, Hyman LD, Limb C, McCarthy S, Lange R, Sherwin RS, et al. Central adiposity and its metabolic correlates in obese adolescent girls. Am J Physiol. 1995;269(1 Pt 1):E118-E126. Not a longitudinal study Wrong measure of OW. [pmid: 7631766].
Caprio S, Bronson M, Sherwin RS, Rife F, Tamborlane WV. Co-existence of severe insulin resistance and hyperinsulinaemia in pre-adolescent obese children. Diabetologia. 1996;39(12):1489-1497. Wrong measure of OW Not a longitudinal study. [pmid: 8960831].
Caprio S, Hyman LD, McCarthy S, Lange R, Bronson M, Tamborlane WV. Fat distribution and cardiovascular risk factors in obese adolescent girls: importance of the intraabdominal fat depot. Am J Clin Nutr. 1996;64(1Jul):12-17. Not a longitudinal study. [pmid: 8669407].
Casey VA, Dwyer JT, Berkey CS, Bailey SM, Coleman KA, Valadian I. The distribution of body fat from childhood to adulthood in a longitudinal study population. Ann Hum Biol. 1994;21(1):39-55. No BMI tracking data. [pmid: 8147576].
Charney E, Goodman HC, McBride M, Lyon B, Pratt R. Childhood antecedents of adult obesity. Do chubby infants become obese adults?. New England Journal of Medicine. 1976;295(1):6-9. Wrong age group. [pmid: 1272299].
Chen W, Srinivasan SR, Elkasabany A, Berenson GS. Cardiovascular risk factors clustering features of insulin resistance syndrome (Syndrome X) in a biracial (black-white) population of children, adolescents, and young adults: the Bogalusa Heart Study. Am J Epidemiol. 1999;150(7):667-674. Not a longitudinal study. [pmid: 10512420].
Chen Y, Dales R, Krewski D, Breithaupt K. Increased effects of smoking and obesity on asthma among female Canadians: the National Population Health Survey, 1994-1995. Am J Epidemiol. 1999;150(3):255-262. Not a longitudinal study Wrong age OW measure. [pmid: 10430229].
Chervin RD, Clarke DF, Huffman JL, Szymanski E, Ruzicka DL, Miller V, et al. School performance, race, and other correlates of sleep-disordered breathing in children. Sleep Medicine. 2003;4(1):21-27. Not a longitudinal study. [pmid: 14592356].
Chinn S. Obesity and asthma: evidence for and against a causal relation. Journal of Asthma. 2003;40(1):1-16. Non-US population. [pmid: 12699207].
Chinn S, Rona RJ. Can the increase in body mass index explain the rising trend in asthma in children?. Thorax. 2001;56(11):845-850. Non-US population. [pmid: 11641508]. [pmcid: 1745960].
Chu NF, Rimm EB, Wang DJ, Liou HS, Shieh SM. Clustering of cardiovascular disease risk factors among obese schoolchildren: the Taipei Children Heart Study. American Journal of Clinical Nutrition. 1998;67(6):1141-1146. Non-US population. [pmid: 9625086].
Chu NF, Wang DJ, Shieh SM, Rimm EB. Plasma leptin concentrations and obesity in relation to insulin resistance syndrome components among school children in Taiwan—The Taipei Children Heart Study. International Journal of Obesity & Related Metabolic Disorders. 2000;24(10):1265-1271. Non-US population. [pmid: 11093287].
Clarke WR, Woolson RF, Lauer RM. Changes in ponderosity and blood pressure in childhood: the Muscatine Study. Am J Epidemiol. 1986;124(2):195-206. Wrong age group. [pmid: 3728436].
Cook DG, Mendall MA, Whincup PH, Carey IM, Ballam L, Morris JE, et al. C-reactive protein concentration in children: relationship to adiposity and other cardiovascular risk factors. Atherosclerosis. 2000;149(1):139-150. Non-US population. [pmid: 10704625].
Cowell JM, Montgomery AC, Talashek M. Cardiovascular risk stability: from grade school to high school. Journal of Pediatric Health Care. 1992;6(6):349-354. Wrong measure of OW Wrong age group. [pmid: 1491318].
Cowin I, Emmett P. Cholesterol and triglyceride concentrations, birthweight and central obesity in pre-school children. ALSPAC Study Team. Avon Longitudinal Study of Pregnancy and Childhood. Int J Obes Relat Metab Disord. 2000;24(3):330-339. Non-US population. [pmid: 10757627].
Cronk CE, Roche AF, Kent R, Berkey C, Reed RB, Valadian I, et al. Longitudinal trends and continuity in weight/stature from 3 months to 18 years. Hum Biol. 1982;54(4):729-749. Trajectory study. [pmid: 7166296].
Dai S, Labarthe DR, Grunbaum JA, Harrist RB, Mueller WH. Longitudinal analysis of changes in indices of obesity from age 8 years to age 18 years. Project HeartBeat!. American Journal of Epidemiology. 2002;156(8):720-729. Normative data only Trajectory study. [pmid: 12370160].
Daniels SR, Kimball TR, Morrison JA, Khoury P, Witt S, Meyer RA. Effect of lean body mass, fat mass, blood pressure, and sexual maturation on left ventricular mass in children and adolescents. Statistical, biological, and clinical significance. Circulation. 1995;92(11):3249-3254. Not a longitudinal study. [pmid: 7586311].
Daniels SR, Obarzanek E, Barton BA, Kimm SY, Similo SL, Morrison JA. Sexual maturation and racial differences in blood pressure in girls: the National Heart, Lung, and Blood Institute Growth and Health Study. Journal of Pediatrics. 1996;129(2):208-213. Not a longitudinal study. [pmid: 8765617].
Datar A, Sturm R, Magnabosco JL. Childhood overweight and academic performance: national study of kindergartners and first-graders 4904. Obesity Research. 2004;12(1):58-68. No adult outcomes. [pmid: 14742843].
Davis SP, Arthur C, Davis M, Goldberg D, Moll G, Davis G. Assessing cardiovascular risk in children: the Jackson, Mississippi CRRIC Study. Journal of Cultural Diversity. 2002;9(3):67-72. Not a longitudinal study. [pmid: 12483999].
Dietz WH. Childhood weight affects adult morbidity and mortality. Journal of Nutrition. 1998;128(2 Suppl):411S-414S. Not a longitudinal study. [pmid: 9478038].
Dietz WH. Overweight in childhood and adolescence. N Engl J Med. 2004;350(9):855-857. Not a longitudinal study. [pmid: 14985480].
DiPietro L, Mossberg HO, Stunkard AJ. A 40-year history of overweight children in Stockholm: life-time overweight, morbidity, and mortality. International Journal of Obesity & Related Metabolic Disorders. 1994;18(9):585-590. Non-US population. [pmid: 7812410].
Douglas MB, Birrer RB, Medidi S, Schlussel YR. Obese children should be screened for hypercholesterolemia. Journal of Health Care for the Poor & Underserved. 1996;7(1):24-35. Not a longitudinal study. [pmid: 8645782].
Dowling AM, Steele JR, Baur LA. Does obesity influence foot structure and plantar pressure patterns in prepubescent children?. International Journal of Obesity & Related Metabolic Disorders. 2001;25(6):845-852. Non-US population. [pmid: 11439299].
Dyer AR, Stamler J, Garside DB, Greenland P. Long-term consequences of body mass index for cardiovascular mortality: The Chicago Heart Association Detection Project in Industry Study. Ann Epidemiol. 2003;14:101-108. Wrong age group. [pmid: 15018882].
Ebbeling CB, Pawlak DB, Ludwig DS. Childhood obesity: public-health crisis, common sense cure. Lancet. 2002;360(9331):473-482. Not a longitudinal study. [pmid: 12241736].
Ellis KJ, Abrams SA, Wong WW. Monitoring childhood obesity: assessment of the weight/height index. American Journal of Epidemiology. 1999;150(9):939-946. Not a longitudinal study. [pmid: 10547139].
Engeland A, Bjorge T, Sogaard AJ, Tverdal A. Body mass index in adolescence in relation to total mortality: 32-year follow-up of 227,000 Norwegian boys and girls. Am J Epidemiol. 2003;157(6):517-523. Non-US population. [pmid: 12631541].
Erickson SJ, Robinson TN, Haydel KF, Killen JD. Are overweight children unhappy?: Body mass index, depressive symptoms, and overweight concerns in elementary school children.[comment]. Archives of Pediatrics & Adolescent Medicine. 2000;154(9):931-935. Not a longitudinal study. [pmid: 10980798].
Eriksson JG, Forsen T, Tuomilehto J, Osmond C, Barker DJ. Early adiposity rebound in childhood and risk of Type 2 diabetes in adult life. Diabetologia. 2003;46(2):190-194. Non-US population. [pmid: 12627317].
Ferraro KF, Thorpe RJ Jr, Wilkinson JA. The life course of severe obesity: does childhood overweight matter?. Journals of Gerontology Series B-Psychological Sciences & Social Sciences. 2003;58(2):S110-S119. Wrong measure of OW.
Figueroa-Munoz JI, Chinn S, Rona RJ. Association between obesity and asthma in 4–11 year old children in the UK. Thorax. 2001;56(2):133-137. Non-US population. [pmid: 11209102]. [pmcid: 1745999].
Ford ES, Galuska DA, Gillespie C, Will JC, Giles WH, Dietz WH. C-reactive protein and body mass index in children: findings from the Third National Health and Nutrition Examination Survey, 1988-1994. J Pediatr. Apr. 2001;138(4):486-92. Not a longitudinal study. [pmid: 11295710].
Freedman DS, Srinivasan SR, Burke GL, Shear CL, Smoak CG, Harsha DW, et al. Relation of body fat distribution to hyperinsulinemia in children and adolescents: the Bogalusa Heart Study. Am J Clin Nutr. 1987;46(3):403-410. Not a longitudinal study. [pmid: 3307372].
Freedman DS, Srinivasan SR, Harsha DW, Webber LS, Berenson GS. Relation of body fat patterning to lipid and lipoprotein concentrations in children and adolescents: the Bogalusa Heart Study. Am J Clin Nutr. 1989;50(5):930-939. Not a longitudinal study. [pmid: 2816800].
Freedman DS, Srinivasan SR, Valdez RA, Williamson DF, Berenson GS. Secular increases in relative weight and adiposity among children over two decades: the Bogalusa Heart Study. Pediatrics. 1997;99(3):420-426. Not a longitudinal study. [pmid: 9041299].
Freedman DS, Dietz WH, Srinivasan SR, Berenson GS. The relation of overweight to cardiovascular risk factors among children and adolescents: the Bogalusa Heart Study. Pediatrics. 1999;103(6 Pt 1):1175-1182. Not a longitudinal study. [pmid: 10353925].
Freedman DS, Serdula MK, Srinivasan SR, Berenson GS. Relation of circumferences and skinfold thicknesses to lipid and insulin concentrations in children and adolescents: the Bogalusa Heart Study. Am J Clin Nutr. 1999;69(2):308-317. Not a longitudinal study. [pmid: 9989697].
Freedman DS, Dietz WH, Tang R, Mensah GA, Bond MG, Urbina EM, et al. The relation of obesity throughout life to carotid intima-media thickness in adulthood: the Bogalusa Heart Study. International Journal of Obesity & Related Metabolic Disorders. 2004;28(1):159-166. Not an outcome of interest. [pmid: 14581934].
Friedman MA, Brownell KD. Psychological correlates of obesity: moving to the next research generation. Psychol Bull. 1995;117(1):3-20. Not a longitudinal study. [pmid: 7870862].
Fung KP, Lee J, Lau SP, Chow OK, Wong TW, Davis DP. Properties and clinical implications of body mass indices. Archives of Disease in Childhood. 1990;65(5):516-519. Non-US population. [pmid: 2357091]. [pmcid: 1792168].
Garn SM, Clark DC. Trends in fatness and the origins of obesity Ad Hoc Committee to Review the Ten-State Nutrition Survey. Pediatrics. 1976;57(4):443-456. Wrong measure of OW. [pmid: 1264536].
Garn SM, Cole PE. Do the obese remain obese and the lean remain lean?. Am J Public Health. Apr. 1980;70(4):351-2. Not a longitudinal study. [pmid: 7361952]. [pmcid: 1619387].
Garn SM, Pilkington JJ, Lavelle M. Relationship between initial fatness level and long-term fatness change. Ecology of Food and Nutrition. 1984;14:85-92. No clear age at OW measurement.
Gasperino J. Ethnic differences in body composition and their relation to health and disease in women. Ethnicity & Health. 1996;1(4):337-347. Not a longitudinal study Wrong age group. [pmid: 9395578].
Gasser T, Ziegler P, Seifert B, Molinari L, Largo RH, Prader A. Prediction of adult skinfolds and body mass from infancy through adolescence. Annals of Human Biology. 1995;22(3):217-233. Non-US population. [pmid: 7574447].
Giacchi M, Mattei R, Rossi S. Correction of the self-reported BMI in a teenage population. International Journal of Obesity & Related Metabolic Disorders. 1998;22(7):673-677. Not a longitudinal study. [pmid: 9705028].
Gidding SS, Bao W, Srinivasan SR, Berenson GS. Effects of secular trends in obesity on coronary risk factors in children: the Bogalusa Heart Study. Journal of Pediatrics. 1995;127(6):868-874. Wrong outcome measure. [pmid: 8523181].
Gidding SS, Leibel RL, Daniels S, Rosenbaum M, Van Horn L, Marx GR. Understanding obesity in youth. A statement for healthcare professionals from the Committee on Atherosclerosis and Hypertension in the Young of the Council on Cardiovascular Disease in the Young and the Nutrition Committee, American Heart Association. Writing Group. Circulation. 1996;94(12):3383-3387. Not a longitudinal study. [pmid: 8989156].
Gillum RF, Taylor HL, Brozek J, Polansky P, Blackburn H. Indices of obesity and blood pressure in young men followed 32 years. J Chronic Dis. 1982;35(3):211-219. Wrong age group. [pmid: 7061678].
Golan M, Weizman A. Reliability and validity of the Family Eating and Activity Habits Questionnaire. European Journal of Clinical Nutrition. 1998;52(10):771-777. No link between OW and subsequent health measures. [pmid: 9805227].
Goodman E, Adler NE, Daniels SR, Morrison JA, Slap GB, Dolan LM. Impact of objective and subjective social status on obesity in a biracial cohort of adolescents. Obesity Research. 2003;11(8):1018-1026. Not a longitudinal study. [pmid: 12917508].
Goran MI. Measurement issues related to studies of childhood obesity: assessment of body composition, body fat distribution, physical activity, and food intake. Pediatrics. 1998;101(3 Pt 2):505-518. Not a longitudinal study. [pmid: 12224657].
Gortmaker SL, Dietz WH Jr, Sobol AM, Wehler CA. Increasing pediatric obesity in the United States. Am J Dis Child. 1987;141(5):535-540. Not a longitudinal study. [pmid: 3578167].
Grilo CM, Wilfley DE, Brownell KD, Rodin J. Teasing, body image, and self-esteem in a clinical sample of obese women. Addict Behav. 1994;19(4):443-450. Wrong age group Not a longitudinal study. [pmid: 7992678].
Gunnell DJ, Frankel SJ, Nanchahal K, Peters TJ, Davey SG. Childhood obesity and adult cardiovascular mortality: a 57-y follow-up study based on the Boyd Orr cohort. American Journal of Clinical Nutrition. 1998;67(6):1111-1118. Non-US population. [pmid: 9625081].
Gutin B, Owens S, Treiber F, Islam S, Karp W, Slavens G. Weight-independent cardiovascular fitness and coronary risk factors. Arch Pediatr Adolesc Med. 1997;151(5):462-465. Not a longitudinal study Wrong measure of OW. [pmid: 9158437].
Gutin B, Treiber F, Owens S, Mensah GA. Relations of body composition to left ventricular geometry and function in children. J Pediatr. 1998;132(6):1023-1027. Not a longitudinal study. [pmid: 9627597].
Hales CN, Barker DJ, Clark PM, Cox LJ, Fall C, Osmond C, et al. Fetal and infant growth and impaired glucose tolerance at age 64. BMJ. 1991;303(6809):1019-1022. Non-US population. [pmid: 1954451]. [pmcid: 1671766].
Halpern CT, Udry JR, Campbell B, Suchindran C. Effects of body fat on weight concerns, dating, and sexual activity: a longitudinal analysis of black and white adolescent girls. Developmental Psychology. 1999;35(3):721-736. Not an outcome of interest. [pmid: 10380863].
Hansson LE, Nyren O, Bergstrom R, Wolk A, Lindgren A, Baron J, et al. Nutrients and gastric cancer risk. A population-based case-control study in Sweden. Int J Cancer. 1994;57(5):638-644. Non-US population. [pmid: 8194870].
Hardy R, Wadsworth M, Kuh D. The influence of childhood weight and socioeconomic status on change in adult body mass index in a British national birth cohort. Int J Obes Relat Metab Disord. 2000;24(6):725-734. Non-US population. [pmid: 10878679].
Hartz AJ, Rimm AA. Natural history of obesity in 6,946 women between 50 and 59 years of age. Amer J Pub Health. 1980;70(4):385-8. Wrong measure of OW. [pmid: 7361956]. [pmcid: 1619382].
He Q, Karlberg J. Prediction of adult overweight during the pediatric years. Pediatric Research. 1999;46(6):697-703. Non-US population. [pmid: 10590026].
He Q, Karlberg J. Probability of adult overweight and risk change during the BMI rebound period. Obesity Research. 2002;10(3):135-140. Non-US population. [pmid: 11886935].
He Q, Ding ZY, Fong DY, Karlberg J. Blood pressure is associated with body mass index in both normal and obese children. Hypertension. 2000;36(2):165-170. Non-US population. [pmid: 10948072].
Health implications of obesity. National Institutes of Health Consensus Development Conference. 11–13 February 1985. Ann Intern Med. 1985 Dec:103(6 ( Pt 2));1073–1077. Wrong age group Not a longitudinal study
Higgins PB, Gower BA, Hunter GR, Goran MI. Defining health-related obesity in prepubertal children. Obes Res. 2001;9(4):233-240. Not a longitudinal study. [pmid: 11331426].
Himes JH, Dietz WH. Guidelines for overweight in adolescent preventive services: recommendations from an expert committee. The Expert Committee on Clinical Guidelines for Overweight in Adolescent Preventive Services. Am J Clin Nutr. 1994;59(2):307-316. Not an outcome of interest. [pmid: 8310979].
Himes JH, Roche AF. Subcutaneous fatness and stature: relationship from infancy to adulthood. Hum Biol. 1986;58(5):737-750. Wrong outcome measure Wrong measure of OW. [pmid: 3804295].
Hoffmans MD, Kromhout D, de Lezenne Coulander C. The impact of body mass index of 78,612 18-year old Dutch men on 32-year mortality from all causes. J Clin Epidemiol. 1988;41(8):749-56. Non-US population. [pmid: 3418364].
Hoffmans MD, Kromhout D, Coulander CD. Body Mass Index at the age of 18 and its effects on 32-year-mortality from coronary heart disease and cancer. A nested case-control study among the entire 1932 Dutch male birth cohort. J Clin Epidemiol. 1989;42(6):513-520. Non-US population. [pmid: 2738614].
Holbrook TL, Barrett-Connor E, Wingard DL. The association of lifetime weight and weight control patterns with diabetes among men and women in an adult community. Int J Obes. 1989;13(5):723-729. Wrong age group. [pmid: 2583926].
Hwang HK, Chen MR, Lee YJ, Lee HC, Huang CY, Kao HA, et al. Metabolic disturbance in obese children: glucose, insulin levels and lipid profile. Acta Paediatrica Taiwanica. 2001;42(2):75-80. Non-US population. [pmid: 11355068].
Hypponen E, Virtanen SM, Kenward MG, Knip M, Akerblom HK. Childhood Diabetes in Finland Study Group. Obesity, increased linear growth, and risk of type 1 diabetes in children. Diabetes Care. 2000;23(12):1755-1760. Non-US population. [pmid: 11128347].
Hypponen E, Power C, Smith GD. Prenatal growth, BMI, and risk of type 2 diabetes by early midlife. Diabetes Care. Sep. 2003;26(9):2512-7. Non-US population. [pmid: 12941711].
Israel AC, Ivanova MY. Global and dimensional self-esteem in preadolescent and early adolescent children who are overweight: age and gender differences. Int J Eat Disord. 2002;31(4):424-429. Not a longitudinal study. [pmid: 11948647].
Jedrychowski W, Maugeri U, Flak E, Mroz E, Bianchi I. Predisposition to acute respiratory infections among overweight preadolescent children: an epidemiologic study in Poland. Public Health. 1998;112(3):189-195. Non-US population. [pmid: 9629027].
Johnson JG, Cohen P, Kasen S, Brook JS. Childhood adversities associated with risk for eating disorders or weight problems during adolescence or early adulthood. American Journal of Psychiatry. 2002;159(3):394-400. Wrong topic area. [pmid: 11870002].
Kaplan TA, Digel SL, Scavo VA, Arellana SB. Effect of obesity on injury risk in high school football players. Clinical Journal of Sport Medicine. 1995;5(1):43-47. Limited to specific group Not an outcome of interest. [pmid: 7614081].
Kawabe H, Shibata H, Hirose H, Tsujioka M, Saito I, Saruta T. Determinants for the development of hypertension in adolescents. A 6-year follow-up. Journal of Hypertension. 2000;18(11):1557-1561. Non-US population. [pmid: 11081767].
Kelly JL, Stanton WR, McGee R, Silva PA. Tracking relative weight in subjects studied longitudinally from ages 3 to 13 years. J Paediatr Child Health. 1992;28(2):158-161. Non-US population. [pmid: 1562367].
Kempers KG, Foote JW, DiFlorio-Brennan T. Obesity: prevalence and considerations in oral and maxillofacial surgery. Journal of Oral & Maxillofacial Surgery. 2000;58(2):137-143. Not a longitudinal study. [pmid: 10670591].
Kikuchi DA, Srinivasan SR, Harsha DW, Webber LS, Sellers TA, Berenson GS. Relation of serum lipoprotein lipids and apolipoproteins to obesity in children: the Bogalusa Heart Study. Preventive Medicine. 1992;21(2):177-190. Not a longitudinal study. [pmid: 1579553].
Klish WJ. Childhood obesity. Pediatr Rev. 1998;19(9):312-315. Not a longitudinal study. [pmid: 9745315].
Koplan JP, Dietz WH. Caloric imbalance and public health policy. JAMA. 1999;282(16):1579-1581. Not a longitudinal study. [pmid: 10546699].
Labarthe DR, Mueller WH, Eissa M. Blood pressure and obesity in childhood and adolescence. Epidemiologic aspects. Annals of Epidemiology. 1991;1(4):337-345. Not a longitudinal study. [pmid: 1669515].
Lai SW, Ng KC, Lin HF, Chen HL. Association between obesity and hyperlipidemia among children. Yale Journal of Biology & Medicine. 2001;74(4):205-210. Non-US population. [pmid: 11697478]. [pmcid: 2588770].
Laitinen J, Power C, Jarvelin MR. Family social class, maternal body mass index, childhood body mass index, and age at menarche as predictors of adult obesity. American Journal of Clinical Nutrition. 2001;74(3):287-294. Non-US population. [pmid: 11522550].
Lake JK, Power C, Cole TJ. Child to adult body mass index in the 1958 British birth cohort: associations with parental obesity. Archives of Disease in Childhood. 1997;77(5):376-381. Wrong measure of OW. [pmid: 9487953].
Lake JK, Power C, Cole TJ. Women's reproductive health: the role of body mass index in early and adult life. Int J Obes Relat Metab Disord. 1997;21(6):432-438. Non-US population. [pmid: 9192225].
Laskarzewski P, Morrison JA, Mellies MJ, Kelly K, Gartside PS, Khoury P, et al. Relationships of measurements of body mass to plasma lipoproteins in schoolchildren and adults. Am J Epidemiol. 1980;111(4):395-406. Not a longitudinal study. [pmid: 7377182].
Lauer RM, Lee J, Clarke WR. Factors affecting the relationship between childhood and adult cholesterol levels: the Muscatine Study. Pediatrics. 1988;82(3):309-318. Same data as Lauer 89. [pmid: 3405659].
Lauer RM, Lee J, Clarke WR. Predicting adult cholesterol levels from measurements in childhood and adolescence: the Muscatine Study. Bulletin of the New York Academy of Medicine. 1989;65(10):1127-1142. Wrong measure of OW. [pmid: 2629967]. [pmcid: 1807893].
Lauer RM, Burns TL, Clarke WR, Mahoney LT. Childhood predictors of future blood pressure. Hypertension. Sep. 1991;18(3 Suppl):I74-81. Not a longitudinal study Wrong measure of OW. [pmid: 1889860].
Laurier D, Guiguet M, Chau NP, Wells JA, Valleron AJ. Prevalence of obesity: a comparative survey in France, the United Kingdom and the United States. International Journal of Obesity & Related Metabolic Disorders. 1992;16(8):565-572. Not a longitudinal study Wrong age group. [pmid: 1326486].
Lazarus R, Colditz G, Berkey CS, Speizer FE. Effects of body fat on ventilatory function in children and adolescents: cross-sectional findings from a random population sample of school children. Pediatric Pulmonology. 1997;24(3):187-194. Non-US population. [pmid: 9330415].
Le Stunff C, Bougneres P. Early changes in postprandial insulin secretion, not in insulin sensitivity, characterize juvenile obesity. Diabetes. 1994;43(5):696-702. Non-US population. [pmid: 8168647].
Lin-Su K, Vogiatzi MG, New MI. Body mass index and age at menarche in an adolescent clinic population. Clinical Pediatrics. 2002;41(7):501-507. Not a longitudinal study. [pmid: 12365312].
Lissau-Lund-Sorensen I, Sorensen TI. Prospective study of the influence of social factors in childhood on risk of overweight in young adulthood. International Journal of Obesity & Related Metabolic Disorders. 1992;16(3):169-175. Non-US population. [pmid: 1317825].
Lissner L, Odell PM, D'Agostino RB, Stokes J III, Kreger BE, Belanger AJ, et al. Variability of body weight and health outcomes in the Framingham population. N Engl J Med. 1991;324(26):1839-1844. Wrong age group. [pmid: 2041550].
Lloyd JK, Wolff OH. Childhood obesity. Br Med J. Jul 15. 1961;5245:145-8. Non-US population. [pmid: 13762916].
Loder RT, Aronson DD, Greenfield ML. The epidemiology of bilateral slipped capital femoral epiphysis. A study of children in Michigan. Journal of Bone & Joint Surgery - American Volume. 1993;75(8):1141-1147. Not a longitudinal study.
Maffeis C, Pietrobelli A, Grezzani A, Provera S, Tato L. Waist circumference and cardiovascular risk factors in prepubertal children. Obes Res. 2001;9(3):179-187. Non-US population. [pmid: 11323443].
Mallory GB Jr, Fiser DH, Jackson R. Sleep-associated breathing disorders in morbidly obese children and adolescents. J Pediatr. 1989;115(6):892-897. Not a longitudinal study. [pmid: 2585224].
Mamalakis G, Kafatos A, Manios Y, Kalogeropoulos N, Andrikopoulos N. Adipose fat quality vs. quantity: relationships with children's serum lipid levels. Preventive Medicine. 2001;33(6):525-535. Non-US population. [pmid: 11716647].
Martin MM, Martin AL. Obesity, hyperinsulinism, and diabetes mellitus in childhood. J Pediatr. 1973;82(2):192-201. Not a longitudinal study. [pmid: 4684363].
Martini G, Riva P, Rabbia F, Molini V, Ferrero GB, Cerutti F, et al. Heart rate variability in childhood obesity. Clinical Autonomic Research. 2001;11(2):87-91. Non-US population. [pmid: 11570608].
McGill HC Jr, McMahan CA, Malcom GT, Oalmann MC, Strong JP. Relation of glycohemoglobin and adiposity to atherosclerosis in youth. Pathobiological Determinants of Atherosclerosis in Youth (PDAY) Research Group. Arterioscler Thromb Vasc Biol. 1995;15(4):431-440. Not a longitudinal study Wrong measure of OW. [pmid: 7749853].
McGill HC Jr, McMahan CA, Herderick EE, Zieske AW, Malcom GT, Tracy RE, et al. Obesity accelerates the progression of coronary atherosclerosis in young men. Circulation. 2002;105(23):2712-2718. Not a longitudinal study. [pmid: 12057983].
McTigue KM, Garrett JM, Popkin BM. The natural history of the development of obesity in a cohort of young U.S. adults between 1981 and 1998.[comment][summary for patients in Ann Intern Med. 2002 Jun 18;136(12):I–24; PMID: 12069570]. Annals of Internal Medicine. 2002;136(12):857-864. Not predicting adult OW by youth OW status. [pmid: 12069559].
Miller FJ, Billewicz WZ, Thomson AM. Growth from birth to adult life of 442 Newcastle upon Tyne children. Br J Prev Soc Med. 1972;26(4):224-230. Non-US population. [pmid: 4658268]. [pmcid: 478725].
Mitchell BM, Gutin B, Kapuku G, Barbeau P, Humphries MC, Owens S, et al. Left ventricular structure and function in obese adolescents: relations to cardiovascular fitness, percent body fat, and visceral adiposity, and effects of physical training. Pediatrics. 2002;109(5):E73. Wrong age group Not a longitudinal study. [pmid: 11986479].
Mokdad AH, Marks JS, Stroup DF, Gerberding JL. Actual causes of death in the United States, 2000. JAMA. 2004;291(10):1238-1245. Not a longitudinal study. [pmid: 15010446].
Molnar D, Livingstone B. Physical activity in relation to overweight and obesity in children and adolescents. European Journal of Pediatrics. 2000;159(Suppl 1):S45-S55. Not a longitudinal study. [pmid: 11011955].
Monti LD, Brambilla P, Stefani I, Caumo A, Magni F, Poma R, et al. Insulin regulation of glucose turnover and lipid levels in obese children with fasting normoinsulinaemia. Diabetologia. 1995;38(6):739-747. Non-US population. [pmid: 7672499].
Moon OR, Kim NS, Jang SM, Yoon TH, Kim SO. The relationship between body mass index and the prevalence of obesity-related diseases based on the 1995 National Health Interview Survey in Korea. Obesity Reviews. 2002;3(3):191-196. Non-US population. [pmid: 12164471].
Morgan CM, Tanofsky-Kraff M, Wilfley DE, Yanovski JA. Childhood obesity. Child & Adolescent Psychiatric Clinics of North America. 2002;11(2):257-278. Not a longitudinal study. [pmid: 12109321].
Morrison JA, Barton BA, Biro FM, Daniels SR, Sprecher DL. Overweight, fat patterning, and cardiovascular disease risk factors in black and white boys. Journal of Pediatrics. 1999;135(4):451-457. Not a longitudinal study. [pmid: 10518096].
Morrison JA, Sprecher DL, Barton BA, Waclawiw MA, Daniels SR. Overweight, fat patterning, and cardiovascular disease risk factors in black and white girls: The National Heart, Lung, and Blood Institute Growth and Health Study. Journal of Pediatrics. 1999;135(4):458-464. Not a longitudinal study. [pmid: 10518079].
Mossberg HO. 40-year follow-up of overweight children. Lancet. 1989;2(8661):491-493. Non-US population. [pmid: 2570196].
Mo-suwan L, Tongkumchum P, Puetpaiboon A. Determinants of overweight tracking from childhood to adolescence: a 5 y follow-up study of Hat Yai schoolchildren. International Journal of Obesity & Related Metabolic Disorders. 2000;24(12):1642-1647. Non-US population. [pmid: 11126218].
Must A. Morbidity and mortality associated with elevated body weight in children and adolescents. Am J Clin Nutr. 1996;63(3 Suppl):445S-447S. Not a longitudinal study. [pmid: 8615339].
Must A. Does overweight in childhood have an impact on adult health?. Nutr Rev. 2003;61(4):139-142. Non-US population. [pmid: 12795448].
Must A, Spadano J, Coakley EH, Field AE, Colditz G, Dietz WH. The disease burden associated with overweight and obesity. JAMA. 1999;282(16):1523-1529. Wrong age group Not a longitudinal study. [pmid: 10546691].
National Center for Health Statistics. Cited 3/29/04. www.cdc.gov/nchs/products/pubs/pubd/hestats/overwght99.htm Prevalence of overweight among children and adolescents: United States, 1999-2000. Not a longitudinal study
Newman WP 3rd, Freedman DS, Voors AW, Gard PD, Srinivasan SR, Cresanta JL, Williamson GD, Webber LS, Berenson GS. Relation of serum lipoprotein levels and systolic blood pressure to early atherosclerosis. The Bogalusa Heart Study. N Engl J Med. Jan 16. 1986;314(3):138-44. Do not report age at OW measurement. [pmid: 3455748].
Oken E, Lightdale JR. Updates in pediatric nutrition. Curr Opin Pediatr. 2000;12(3):282-290. Not a longitudinal study. [pmid: 10836167].
Oren A, Vos LE, Uiterwaal CS, Bak AA, Gorissen WH, Grobbee DE, et al. The Atherosclerosis Risk in Young Adults (ARYA) study: rationale and design. European Journal of Epidemiology. 2003;18(7):715-727. Non-US population. [pmid: 12952149].
Paffenbarger RS Jr, Wolf PA, Notkin J, Thorne MC. Chronic disease in former college students. I. Early precursors of fatal coronary heart disease. Am J Epidemiol. Mar. 1966;83(2):314-28. Poor quality rating. [pmid: 5930778].
Palasciano G, Portincasa P, Vinciguerra V, Velardi A, Tardi S, Baldassarre G, et al. Gallstone prevalence and gallbladder volume in children and adolescents: an epidemiological ultrasonographic survey and relationship to body mass index. American Journal of Gastroenterology. 1989;84(11):1378-1382. Non-US population. [pmid: 2683739].
Peckham CS, Stark O, Simonite V, Wolff OH. Prevalence of obesity in British children born in 1946 and 1958. British Medical Journal Clinical Research Ed. 1983;286(6373):1237-1242. Non-US population. [pmid: 6404405]. [pmcid: 1547253].
Phillips RG, Hill AJ. Fat, plain, but not friendless: self-esteem and peer acceptance of obese pre-adolescent girls. International Journal of Obesity & Related Metabolic Disorders. 1998;22(4):287-293. Non-US population. [pmid: 9578232].
Pinhas-Hamiel O, Dolan LM, Daniels SR, Standiford D, Khoury PR, Zeitler P. Increased incidence of non-insulin-dependent diabetes mellitus among adolescents. J Pediatr. May. 1996;128(5 Pt 1):608-15. Not a longitudinal study. [pmid: 8627431].
Plourde G. Impact of obesity on glucose and lipid profiles in adolescents at different age groups in relation to adulthood. BMC Family Practice. 2002;3(1):18. Non-US population. [pmid: 12379160]. [pmcid: 134463].
Power C, Li L, Manor O. A prospective study of limiting longstanding illness in early adulthood. International Journal of Epidemiology. 2000;29(1):131-139. Non-US population. [pmid: 10750615].
Prokopec M, Bellisle F. Adiposity in Czech children followed from 1 month of age to adulthood: analysis of individual BMI patterns. Annals of Human Biology. 1993;20(6):517-525. Non-US population. [pmid: 8257077].
Ramirez-Lopez G, Gonzalez-Villalpando C, Sanchez-Corona J, Salmeron-Castro J, Gonzalez-Ortiz M, Celis-de la Rosa A, et al. Weight, physical activity, and smoking as determinants of insulinemia in adolescents. Archives of Medical Research. 2001;32(3):208-213. Non-US population. [pmid: 11395186].
Redline S, Tishler PV, Schluchter M, Aylor J, Clark K, Graham G. Risk factors for sleep-disordered breathing in children. Associations with obesity, race, and respiratory problems. American Journal of Respiratory & Critical Care Medicine. 1999;159(5 Pt 1):1527-1532. Not a longitudinal study. [pmid: 10228121].
Reilly JJ. Assessment of childhood obesity: national reference data or international approach?. Obes Res. 2002;10(8):838-840. Not a longitudinal study. [pmid: 12181394].
Reilly JJ, Dorosty AR. Epidemic of obesity in UK children. Lancet. 1999;354(9193):1874-1875. Non-US population. [pmid: 10584727].
Reilly JJ, Ventham JC, Newell J, Aitchison T, Wallace WH, Gibson BE. Risk factors for excess weight gain in children treated for acute lymphoblastic leukaemia. International Journal of Obesity & Related Metabolic Disorders. 2000;24(11):1537-1541. Not a longitudinal study. [pmid: 11126353].
Reinehr T, Andler W. Thyroid hormones before and after weight loss in obesity. Archives of Disease in Childhood. 2002;87(4):320-323. Not a longitudinal study. [pmid: 12244007]. [pmcid: 1763034].
Resnicow K, Futterman R, Vaughan RD. Body mass index as a predictor of systolic blood pressure in a multiracial sample of US schoolchildren. Ethnicity & Disease. 1993;3(4):351-361. Not a longitudinal study. [pmid: 7888986].
Rhoads GG, Kagan A. The relation of coronary disease, stroke, and mortality to weight in youth and in middle age. Lancet. 1983;1(8323):492-495. Wrong age group. [pmid: 6131209].
Ribeiro J, Guerra S, Pinto A, Oliveira J, Duarte J, Mota J. Overweight and obesity in children and adolescents: relationship with blood pressure, and physical activity. Annals of Human Biology. 2003;30(2):203-213. Non-US population. [pmid: 12637195].
Richards GE, Cavallo A, Meyer WJ III, Prince MJ, Peters EJ, Stuart CA, et al. Obesity, acanthosis nigricans, insulin resistance, and hyperandrogenemia: pediatric perspective and natural history. J Pediatr. 1985;107(6):893-897. Not a longitudinal study Limited to a specific disease group. [pmid: 2933497].
Rich-Edwards JW, Goldman MB, Willett WC, Hunter DJ, Stampfer MJ, Colditz GA, et al. Adolescent body mass index and infertility caused by ovulatory disorder. American Journal of Obstetrics & Gynecology. 1994;171(1):171-177. Wrong age group. [pmid: 8030695].
Riddiford-Harland DL, Steele JR, Storlien LH. Does obesity influence foot structure in prepubescent children?. Int J Obes Relat Metab Disord. 2000;24(5):541-544. Non-US population. [pmid: 10849573].
Riley DJ, Santiago TV, Edelman NH. Complications of obesity-hypoventilation syndrome in childhood. Am J Dis Child. 1976;130(6):671-674. Not a longitudinal study Limited to a specific disease group. [pmid: 937287].
Rimm IJ, Rimm AA. Association between juvenile onset obesity and severe adult obesity in 73, 532 women. Am J Public Health. 1976;66(5):479-481. Wrong measure of OW. [pmid: 1275125]. [pmcid: 1653295].
Robinson C, Tamborlane WV, Maggs DG, Enoksson S, Sherwin RS, Silver D, Shulman GI, Caprio S. Effect of insulin on glycerol production in obese adolescents. Endocrinol Metab. 1998;37:E737-43. Not a longitudinal study Wrong measure of OW.
Rolland-Cachera MF, Deheeger M, Bellisle F, Sempe M, Guilloud-Bataille M, Patois E. Adiposity rebound in children: a simple indicator for predicting obesity. Am J Clin Nutr. 1984;39(1):129-135. Non-US population. [pmid: 6691287].
Rolland-Cachera MF, Deheeger M, Guilloud-Bataille M, Avons P, Patois E, Sempe M. Tracking the development of adiposity from one month of age to adulthood. Ann Hum Biol. 1987;14(3):219-229. Non-US population. [pmid: 3662424].
Rolland-Cachera MF, Bellisle F, Sempe M. The prediction in boys and girls of the weight/height index and various skinfold measurements in adults: a two-decade follow-up study. International Journal of Obesity. 1989;13(3):305-311. Non-US population. [pmid: 2767883].
Rudolf MC, Greenwood DC, Cole TJ, Levine R, Sahota P, Walker J, et al. Rising obesity and expanding waistlines in schoolchildren: a cohort study. Archives of Disease in Childhood. 2004;89(3):235-237. Non-US population. [pmid: 14977700]. [pmcid: 1719814].
Russo A, Franceschi S, La Vecchia C, Dal Maso L, Montella M, Conti E, et al. Body size and colorectal-cancer risk. International Journal of Cancer. 1998;78(2):161-165. Non-US population.
Saitoh H, Kamoda T, Nakahara S, Hirano T, Nakamura N. Serum concentrations of insulin, insulin-like growth factor(IGF)-I, IGF binding protein (IGFBP)-1 and -3 and growth hormone binding protein in obese children: fasting IGFBP-1 is suppressed in normoinsulinaemic obese children. Clinical Endocrinology. 1998;48(4):487-492. Non-US population. [pmid: 9640416].
Salbe AD, Weyer C, Lindsay RS, Ravussin E, Tataranni PA. Assessing risk factors for obesity between childhood and adolescence: I. Birth weight, childhood adiposity, parental obesity, insulin, and leptin. Pediatrics. 2002;110(2 Pt 1):299-306. Wrong age group. [pmid: 12165582].
Sangi H, Mueller WH, Harrist RB, Rodriguez B, Grunbaum JG, Labarthe DR. Is body fat distribution associated with cardiovascular risk factors in childhood?. Annals of Human Biology. 1992;19(6):559-578. Not a longitudinal study. [pmid: 1476412].
Sargent JD, Blanchflower DG. Obesity and stature in adolescence and earnings in young adulthood. Analysis of a British birth cohort. Arch Pediatr Adolesc Med. Jul. 1994;148(7):681-7. Non-US population. [pmid: 8019620].
Schachter LM, Peat JK, Salome CM. Asthma and atopy in overweight children. Thorax. 2003;58(12):1031-1035. Non-US population. [pmid: 14645967]. [pmcid: 1746556].
Seminara S, Filpo A, La Cauza F, Faedda A, Miola A, Pellizzone S, et al. Growth hormone binding protein activity in obese children. Journal of Endocrinological Investigation. 1998;21(7):441-444. Non-US population. [pmid: 9766258].
Sharp GB, Cole P. Identification of risk factors for diethylstilbestrol-associated clear cell adenocarcinoma of the vagina: similarities to endometrial cancer. American Journal of Epidemiology. 1991;134(11):1316-1324. Not a longitudinal study Not an outcome of interest. [pmid: 1755445].
Sharp TA, Grunwald GK, Giltinan KE, King DL, Jatkauskas CJ, Hill JO. Association of anthropometric measures with risk of diabetes and cardiovascular disease in Hispanic and Caucasian adolescents. Preventive Medicine. 2003;37(6 Pt 1):611-616. Not a longitudinal study. [pmid: 14636794].
Shear CL, Freedman DS, Burke GL, Harsha DW, Berenson GS. Body fat patterning and blood pressure in children and young adults: The Bogalusa Heart Study. Hypertension. 1987;9:236-244. Not a longitudinal study. [pmid: 3818021].
Siervogel RM, Roche AF, Guo SM, Mukherjee D, Chumlea WC. Patterns of change in weight/stature2 from 2 to 18 years: findings from long-term serial data for children in the Fels longitudinal growth study. Int J Obes. 1991;15(7):479-485. Wrong age group. [pmid: 1845371].
Siervogel RM, Wisemandle W, Maynard LM, Guo SS, Chumlea WC, Towne B. Lifetime overweight status in relation to serial changes in body composition and risk factors for cardiovascular disease: The Fels Longitudinal Study. Obesity Research. 2000;8(6):422-430. Wrong age group. [pmid: 11011908].
Sinha R, Fisch G, Teague B, Tamborlane WV, Banyas B, Allen K, et al. Prevalence of impaired glucose tolerance among children and adolescents with marked obesity. New England Journal of Medicine. 2002;346(11):802-810. Not a longitudinal study. [pmid: 11893791].
Slyper AH. Childhood obesity, adipose tissue distribution, and the pediatric practitioner. Pediatrics. 1998:102(1) Part 1 of 3; 131. Not a longitudinal study
Smoak CG, Burke GL, Webber LS, Harsha DW, Srinivasan SR, Berenson GS. Relation of obesity to clustering of cardiovascular disease risk factors in children and young adults. The Bogalusa Heart Study. Am J Epidemiol. 1987;125(3):364-372. Not a longitudinal study. [pmid: 3544817].
Sokol RJ. The chronic disease of childhood obesity: the sleeping giant has awakened. J Pediatr. 2000;136(6):711-713. Not a longitudinal study.
Somerville SM, Rona RJ, Chinn S. Obesity and respiratory symptoms in primary school. Archives of Disease in Childhood. 1984;59(10):940-944. Non-US population. [pmid: 6497430]. [pmcid: 1628866].
Sorensen TI, Sonne-Holm S. Mortality in extremely overweight young men. J Chronic Dis. 1977;30(6):359-367. Non-US population. [pmid: 874040].
Sorensen TI, Sonne-Holm S. Risk in childhood of development of severe adult obesity: retrospective, population-based case-cohort study. American Journal of Epidemiology. 1988;127(1):104-113. Non-US population. [pmid: 3337071].
Stark O, Atkins E, Wolff OH, Douglas JW. Longitudinal study of obesity in the National Survey of Health and Development. British Medical Journal Clinical Research Ed. 1981;283(6283):13-17. Non-US population. [pmid: 6788242]. [pmcid: 1506053].
Steinbeck KS, Bermingham MA, Mahajan D, Baur LA. Low-density lipoprotein subclasses in children under 10 years of age. Journal of Paediatrics & Child Health. 2001;37(6):550-553. Non-US population. [pmid: 11903833].
Stettler N, Kumanyika SK, Katz SH, Zemel BS, Stallings VA. Rapid weight gain during infancy and obesity in young adulthood in a cohort of African Americans.[comment]. American Journal of Clinical Nutrition. 2003;77(6):1374-1378. Wrong age group. [pmid: 12791612].
Stewart KJ, Brown CS, Hickey CM, McFarland LD, Weinhofer JJ, Gottlieb SH. Physical fitness, physical activity, and fatness in relation to blood pressure and lipids in preadolescent children. Results from the FRESH Study. Journal of Cardiopulmonary Rehabilitation. 1995;15(2):122-129. Not a longitudinal study. [pmid: 8542515].
Stoll BA. Teenage obesity in relation to breast cancer risk. International Journal of Obesity & Related Metabolic Disorders. 1998;22(11):1035-1040. Not a longitudinal study Not an outcome of interest. [pmid: 9822939].
Stradmeijer M, Bosch J, Koops W, Seidell J. Family functioning and psychosocial adjustment in overweight youngsters. Int J Eat Disord. Jan. 2000;27(1):110-4. Non-US population. [pmid: 10590457].
Strauss R. Childhood obesity. Curr Probl Pediatr. 1999;29(1):1-29. Not a longitudinal study. [pmid: 9919427].
Strauss RS, Mir HM. Smoking and weight loss attempts in overweight and normal-weight adolescents. International Journal of Obesity & Related Metabolic Disorders. 2001;25(9):1381-1385. Not a longitudinal study Not an outcome of interest. [pmid: 11571603].
Strauss RS, Pollack HA. Social marginalization of overweight children. Arch Pediatr Adolesc Med. 2003;157(8):746-752. Not a longitudinal study. [pmid: 12912779].
Striegel-Moore RH, Schreiber GB, Lo A, Crawford P, Obarzanek E, Rodin J. Eating disorder symptoms in a cohort of 11 to 16-year-old black and white girls: the NHLBI Growth and Health Study. National Heart, Lung, and Blood Institute. Int J Eat Disord. 2000;27(1Jan):49-66. Not a longitudinal study for obesity. [pmid: 10590449].
Stunkard AJ, Sobal J. Psychosocial consequences of obesity. In: Brownell KD, Fairburn C, editors. Eating Disorders and Obesity: A Comprehensive Handbook. New York: Guilford Press, 1995: 417–421. Not a longitudinal study
Tanofsky-Kraff M, Yanovski SZ, Wilfley DE, Marmarosh C, Morgan CM, Yanovski JA. Eating-Disordered Behaviors, Body Fat, and Psychopathology in Overweight and Normal-Weight Children. Journal of Consulting & Clinical Psychology. 2004;Vol 72(1):61. Not a longitudinal study.
Tershakovec AM, Jawad AF, Stallings VA, Cortner JA, Zemel BS, Shannon BM. Age-related changes in cardiovascular disease risk factors of hypercholesterolemic children. J Pediatr. Mar. 1998;132(3 Pt 1):414-20. Not a longitudinal study Limited to a specific disease group. [pmid: 9544893].
Tershakovec AM, Kuppler KM, Zemel BS, Katz L, Weinzimer S, Harty MP, et al. Body composition and metabolic factors in obese children and adolescents. International Journal of Obesity & Related Metabolic Disorders. 2003;27(1):19-24. Not a longitudinal study Wrong measure of OW. [pmid: 12532149].
Thomson CC, Clark S, Camargo CA Jr. Investigators MARC. Body mass index and asthma severity among adults presenting to the emergency department. Chest. 2003;124(3):795-802. Wrong age group. [pmid: 12970000].
Tounian P, Aggoun Y, Dubern B, Varille V, Guy-Grand B, Sidi D, et al. Presence of increased stiffness of the common carotid artery and endothelial dysfunction in severely obese children: a prospective study. Lancet. 2001;358(9291):1400-1404. Non-US population. [pmid: 11705484].
Tulio S, Egle S, Greily B. Blood pressure response to exercise of obese and lean hypertensive and normotensive male adolescents. Journal of Human Hypertension. 1995;9:953-8. Non-US population. [pmid: 8746639].
Uchiyama M. Risk factors for the development of essential hypertension: long-term follow-up study in junior high school students in Niigata, Japan. Journal of Human Hypertension. 1994;8(5):323-325. Non-US population. [pmid: 8064777].
Urbina EM, Gidding SS, Bao W, Pickoff AS, Berdusis K, Berenson GS. Effect of body size, ponderosity, and blood pressure on left ventricular growth in children and young adults in the Bogalusa Heart Study. Circulation. 1995;91(9):2400-2406. Wrong age group. [pmid: 7729027].
Valle M, Gascon F, Martos R, Ruz FJ, Bermudo F, Rios R, et al. Infantile obesity: a situation of atherothrombotic risk?. Metabolism: Clinical & Experimental. 2000;49(5):672-675. Non-US population. [pmid: 10831182].
Valle M, Gascon F, Martos R, Ruz FJ, Bermudo F, Morales R, et al. Metabolic cardiovascular syndrome in obese prepubertal children: the role of high fasting insulin levels. Metabolism: Clinical & Experimental. 2002;51(4):423-428. Non-US population. [pmid: 11912547].
Valle M, Gascon F, Martos R, Bermudo F, Ceballos P, Suanes A. Relationship between high plasma leptin concentrations and metabolic syndrome in obese pre-pubertal children. International Journal of Obesity & Related Metabolic Disorders. 2003;27(1):13-18. Non-US population. [pmid: 12532148].
Vanhala MJ, Vanhala PT, Keinanen-Kiukaanniemi SM, Kumpusalo EA, Takala JK. Relative weight gain and obesity as a child predict metabolic syndrome as an adult. International Journal of Obesity & Related Metabolic Disorders. 1999;23(6):656-659. Non-US population. [pmid: 10411241].
Vastag B. Obesity Is Now on Everyone's Plate. JAMA. 2004;291(10):1186-1188. Not a longitudinal study. [pmid: 15010429].
Visser M, Bouter LM, McQuillan GM, Wener MH, Harris TB. Low-grade systematic inflammation in overweight children. Pediatrics. 2001;107(1):e13. Not a longitudinal study. [pmid: 11134477].
Von Eyben FE, Mouritsen E, Holm J, Montvilas P, Dimcevski G, Suciu G, Helleberg I, Kristensen L, von Eyben R. Intra-abdominal obesity and metabolic risk factors: A study of young adults. International Journal of Obesity. 2003;27:941-9. Non-US population. [pmid: 12861235].
von Mutius E, Schwartz J, Neas LM, Dockery D, Weiss ST. Relation of body mass index to asthma and atopy in children: the National Health and Nutrition Examination Study III. Thorax. 2001;56(11):835-838. Not a longitudinal study. [pmid: 11641506]. [pmcid: 1745951].
Wabitsch M, Hauner H, Heinze E, Muche R, Bockmann A, Parthon W, Mayer H, Teller W. Body-fat distribution and changes in the atherogenic risk-factor profile in obese adolescent girls during weight reduction. Am J Clin Nutr. Jul. 1994;60(1):54-60. Non-US population. [pmid: 8017338].
Waldhor T, Schober E, Rami B. Austrian Diabetes Incidence Study Group. Regional distribution of risk for childhood diabetes in Austria and possible association with body mass index. European Journal of Pediatrics. 2003;162(6):380-384. Non-US population. [pmid: 12756559].
Wang G, Dietz WH. Economic burden of obesity in youths aged 6 to 17 years: 1979-1999. Pediatrics. 2002;109(5):E81. Not a longitudinal study. [pmid: 11986487].
Washino K, Takada H, Nagashima M, Iwata H. Significance of the atherosclerogenic index and body fat in children as markers for future, potential coronary heart disease. Pediatrics International. 1999;41(3):260-265. Non-US population. [pmid: 10365574].
Wattigney WA, Harsha DW, Srinivasan SR, Webber LS, Berenson GS. Increasing impact of obesity on serum lipids and lipoproteins in young adults. The Bogalusa Heart Study. Archives of Internal Medicine. 1991;151(10):2017-2022. Not a longitudinal study. [pmid: 1929690].
Watts K, Beye P, Siafarikas A, O'Driscoll G, Jones TW, Davis EA, Green DJ. Effects of exercise training on vascular function in obese children. J Pediatr. May. 2004;144(5):620-5. Non-US population. [pmid: 15126996].
Wild RA. Hyperandrogenism in the adolescent. Pediatric & Adolescent Gynecology. 1992;19(1):71-89. Not a longitudinal study Limited to a specific disease group.
Williams CL, Hayman LL, Daniels SR, Robinson TN, Steinberger J, Paridon S, et al. Cardiovascular health in childhood: A statement for health professionals from the Committee on Atherosclerosis, Hypertension, and Obesity in the Young (AHOY) of the Council on Cardiovascular Disease in the Young, American Heart Association. Circulation. 2002;106(1):143-160. Not a longitudinal study. [pmid: 12093785].
Williams DP, Going SB, Lohman TG, Harsha DW, Srinivasan SR, Webber LS, et al. Body fatness and risk for elevated blood pressure, total cholesterol, and serum lipoprotein ratios in children and adolescents. Am J Public Health. 1992;82(3Mar):358-363. Not a longitudinal study. [pmid: 1536350]. [pmcid: 1694353].
Williams S, Dickson N. Early growth, menarche, and adiposity rebound. Lancet. 2002;359(9306):580-581. Non-US population. [pmid: 11867115].
Williams S, Davie G, Lam F. Predicting BMI in young adults from childhood data using two approaches to modelling adiposity rebound. Int J Obes Relat Metab Disord. 1999;23(4):348-354. Non-US population. [pmid: 10340811].
Xu B, Pekkanen J, Laitinen J, Jarvelin MR. Body build from birth to adulthood and risk of asthma. European Journal of Public Health. 2002;12(3):166-170. Non-US population. [pmid: 12232953].
Young TK, Dean HJ, Flett B, Wood-Steiman P. Childhood obesity in a population at high risk for type 2 diabetes. Journal of Pediatrics. 2000;136(3):365-369. Non-US population. [pmid: 10700694].
Young-Hyman D, Schlundt DG, Herman L, De Luca F, Counts D. Evaluation of the insulin resistance syndrome in 5- to 10-year-old overweight/obese African-American children. Diabetes Care. 2001;24(8):1359-1364. Not a longitudinal study. [pmid: 11473070].
Youssef AA, Valdez R, Elkasabany A, Srinivasan SR, Berenson GS. Time-course of adiposity and fasting insulin from childhood to young adulthood in offspring of parents with coronary artery disease: the Bogalusa Heart Study. Annals of Epidemiology. 2002;12(8):553-559. Wrong exposure measure. [pmid: 12495828].
Zack PM, Harlan WR, Leaverton PE, Cornoni-Huntley J. A longitudinal study of body fatness in childhood and adolescence. Journal of Pediatrics. 1979;95(1):126-130. Wrong age group. [pmid: 479994].