# Appendix F. Inclusion Criteria and Results of Searches

Key Questions | Inclusion Criteria | # of Abstracts* Reviewed | Articles reviewed from Abstracts and Outside Sources | # of Articles Meeting Inclusion Criteria
KQ1: Is there direct evidence that screening for overweight in childhood improves age-appropriate behavioral or physiologic measures, or health outcomes? | English abstract; RCT or CCT; US population; Age ≥2 and ≤18; Primary care feasible screening test; Acceptable reference standard; met USPSTF quality grade of good or fair. | 2162 | 0 | 0
KQ2a: What are appropriate standards for overweight in childhood and what is the prevalence of overweight based on these? | Same as KQ1; for prevalence, representative sample or underreported special populations | 2162 | 69 | 5
KQ2b: What clinical screening tests for overweight in childhood are reliable and valid in predicting obesity in adulthood? | English, US population; examine the relationship between overweight in childhood and adult health status relating to overweight; used primary care feasible measures; longitudinal studies; children aged 2–17, adults aged 18 or older; clear definition of childhood overweight measures and status; using adult measure of health status; clear definition of adult disease/health status, or overweight status, controlled for appropriate confounders (age, sex); clearly defined cohort; all examined at the same stage (age group) used representative population standard as comparison; met USPSTF quality grade of good or fair. | 2162 | 284 | 36
KQ2c: What clinical screening tests for overweight in childhood are reliable and valid in predicting poor health outcomes in adulthood?
KQ3: What are the adverse effects of screening, including labeling? Is screening acceptable to patients? | Study includes a screening or intervention component, delivered by a professional; study explicitly evaluates or discusses harms; Screen/intervention is one that has been included in report; Population 2–18 or sub-group analysis for this age group; Meets study quality criteria | 312 | 9 | 0
KQ4: Do weight control interventions lead to improved intermediate outcomes, including behavioral, physiologic or weight-related measures? | English; RCT; US or similarly industrialized countries; age ≥2 and ≤18 with or without family; not specific patient groups such as disease specific populations; enrolled children who are overweight/at-risk for overweight; delivered by any professional; primary care feasible; intervention treats obesity; ≥ 6 mo. follow-up; report baseline and post-intervention measures of weight; clear definition of overweight/at-risk for overweight; good or fair USPSTF quality grade. | 949 | 198 | 22
KQ5: Do weight control interventions lead to improved health outcomes, including decreased morbidity, and/or improved functioning (school attendance, self-esteem and other psychosocial indicators)? | | | | 3
KQ6: What are the adverse effects of interventions? Are interventions acceptable to patients? | Study includes a screening or intervention component, delivered by a professional; study explicitly evaluates or discusses harms; Screen/intervention is one that has been included in report; Longitudinal; Population 2–18 or sub-group analysis for this age group; Meets study quality criteria | 864 | 27 | 4
KQ7: Are improvements in intermediate outcomes associated with improved health outcomes? (Only evaluated if there is no direct evidence for KQ1 or KQ5 and if there is sufficient evidence for KQ4.)

* All abstracts were reviewed for applicability to other key questions.