# Appendix E. Previously Conducted Systematic Evidence Reviews of Interventions for Childhood Overweight

A large number of reviews related to obesity interventions were located during this process (n=17). Seven of them were review articles that did not meet criteria for systematic reviews, ^1^ – ^7^ such as not stating literature retrieval strategies or inclusion/exclusion criteria or not systematically assessing methodologic quality. One systematic evidence review (SERs) in process at the time of our review shared their list of studies addressing childhood obesity treatments (M. Maglione [maglione@rand.org], e-mail, January 23, 2004). We located six SERs or meta-analyses of treatment; three were rated good ^8^ – ^10^ and two were rated fair due to limiting searching to published studies ^11^ or to lack of recency. ^12^ One ^13^ was rated poor due to including a wide range of short-term, uncontrolled or unrandomized studies and to not formally rating methodologic quality of included studies, as was its follow-up. ^14^ Two articles were evidence-based guidelines based on systematic reviews we had already located. ^15,^ ^16^ Two other systematic reviews addressing obesity prevention were excluded as outside our scope due to primarily school-based research. ^17,^ ^18^

In addition to the intervention trials located through our literature searches, we examined all trials (n=18) in the Summerbell review. We also searched the same databases and time period for publications cited as “awaiting assessment”. We examined all intervention articles that were not included in the Summerbell SER but were listed in the other five SERs/meta-analyses, were located as part of the ongoing RAND obesity review, or were cited in the two evidence-based guidelines for pediatric obesity treatment.

Table E-1 Previously Conducted Systematic Evidence Reviews (SERs) of Interventions for Childhood Overweight

SER Title | Author, Source, Pub Date | End Search Date | Scope and Number of Studies | Relevance to Key Questions | USPSTF Quality Rating
Interventions for treating obesity in children | Summerbell et al 2003 ^8^ | 1985-7/2001 | Children | KQ #4 | GOOD
| | | Treatment: N=18
Obesity: diagnosis, prevention, and treatment; evidence based answers to common questions | Reilly et al 2002 ^9^ | 1/1981-6/2000 | Children | KQ #2 | GOOD
| | | Prevention: N=2 | KQ #4
| | | Screening: N=16
| | | Treatment: N=3
| | | Prevalence in UK: N=3
Physical activity interventions in the prevention and treatment of pediatric obesity: systematic review and critical appraisal | Reilly JJ. In Press. Proc Nutr Soc. | 6/2000-5/2002 | Children | KQ #4 | GOOD
| | | Prevention: N=3 | (KQ# 3,6 - discusses studies that report adverse effects but does not systematically review)
| | | Treatment: N= 1 RCT, 1 meta-analysis (Le Mura & Maziekas 2002 - negative quality rating)
The treatment and prevention of obesity: A systematic review of the literature | Glenny et al 1997 ^12^ | 1/1997 | Adults and children | KQ #4 | FAIR due to lack of recency
| | | N=13 studies in children (1 prevention, 12 treatment)
Family involvement in weight control, weight maintenance and weight-loss interventions: a systematic review of randomised trials | McLean et al 2003 ^11^ | Medline® 1966-2000; PsycLIT 1971-2000 | Adults and children | KQ #4 | FAIR due to limiting searching to published studies
| | | Treatment studies with family involvement
| | | N=8 studies in children or adolescents
Factors that alter body fat, body mass, and fat-free mass in pediatric obesity | LeMura and Maziekas 2002 ^13^ | 1960-2001 | Children | KQ #4 | POOR due to including a wide range of short-term, uncontrolled, non-randomized studies and not formally rating methodological quality of included studies
| | | Treatment studies involving exercise
| | | N=7 RCTs,
| | | N=6 CCTs,
| | | N= 17 uncontrolled studies
Follow up exercise studies in paediatric obesity: implications for long term effectiveness | Maziekas et al 2003 ^14^ | 1960-2002 | Children | KQ #4 | POOR due to including a wide range of uncontrolled, non-randomized studies and not formally rating methodological quality of included studies
| | | Treatment studies involving exercise
| | | N = 2 RCTs
| | | N = 2 CCTs
| | | N = 4 uncontrolled studies

## References for Appendix E

1 Epstein LH, Myers MD, Raynor HA, Saelens BE. Treatment of pediatric obesity. Pediatrics. 1998;101(3 Pt 2):554-570. [pmid: 12224662].
2 Goldfield GS, Raynor HA, Epstein LH. Treatment of pediatric obesity. In: Wadden TA, Stunkard AJ, editors. Handbook of Obesity Treatment. New York: Guilford Press, 2002: 532–555.
3 Jelalian E, Saelens BE. Empirically supported treatments in pediatric psychology: pediatric obesity. Journal of Pediatric Psychology. 1999;24(3):223-248. [pmid: 10379137].
4 Epstein LH, Coleman KJ, Myers MD. Exercise in treating obesity in children and adolescents. Med Sci Sports Exerc. 1996;28(4):428-435. [pmid: 8778547].
5 Robinson TN. Behavioural treatment of childhood and adolescent obesity. International Journal of Obesity & Related Metabolic Disorders. 1999;23(Suppl 2):552-557.
6 Jeffery RW, Drewnowski A, Epstein LH, Stunkard AJ, Wilson GT, Wing RR, et al. Long-term maintenance of weight loss: current status. Health Psychol. 2000;19(1 Suppl):5-16. [pmid: 10709944].
7 Yanovski JA. Intensive therapies for pediatric obesity. Pediatric Clinics of North America. 2001;48(4):1041-1053. [pmid: 11494637].
8 Summerbell CD, Ashton V, Campbell KJ, Edmunds L, Kelly S, Waters E. Interventions for treating obesity in children [Systematic Review]. Cochrane Database of Systematic Reviews 2003;(3):CD001872.
9 Reilly JJ, Wilson ML, Summerbell CD, Wilson DC. Obesity: diagnosis, prevention, and treatment; evidence based answers to common questions. Arch Dis Child. 2002;86(6):392-394. [pmid: 12023163]. [pmcid: 1762983].
10 Reilly JJ, McDowell ZC. Physical activity interventions in the prevention and treatment of paediatric obesity: systematic review and critical appraisal. Proceedings of the Nutrition Society. 2003;62(3):611-619. [pmid: 14692597].
11 McLean N, Griffin S, Toney K, Hardeman W. Family involvement in weight control, weight maintenance and weight-loss interventions: a systematic review of randomised trials. International Journal of Obesity & Related Metabolic Disorders. 2003;27(9):987-1005. [pmid: 12917703].
12 Glenny AM, O'Meara S, Melville A, Sheldon TA, Wilson C. The treatment and prevention of obesity: a systematic review of the literature. Int J Obes Relat Metab Disord. 1997;21(9):715-737. [pmid: 9376884].
13 LeMura LM, Maziekas MT. Factors that alter body fat, body mass, and fat-free mass in pediatric obesity. Medicine & Science in Sports & Exercise. 2002;34(3):487-496. [pmid: 11880814].
14 Maziekas MT, LeMura LM, Stoddard NM, Kaercher S, Martucci T. Follow up exercise studies in paediatric obesity: implications for long term effectiveness. British Journal of Sports Medicine. 2003;37(5):425-429. [pmid: 14514534]. [pmcid: 1751365].
15 Scottish Intercollegiate Guidelines Network. Management of Obesity in Children and Young People. A National Clinical Guideline. 2003. Edinburgh, Scottish Intercollegiate Guidelines Network.
16 The prevention and treatment of childhood obesity. Effective Health Care 2002; 7(6):1–11 (67 ref).
17 Campbell K, Waters E, O'Meara S, Kelly S, Summerbell C. Interventions for preventing obesity in children.[update of Cochrane Database Syst Rev. 2001;(3):CD001871; PMID: 11686999]. Cochrane Database of Systematic Reviews 2002;(2):CD001871.
18 Jerum A, Melnyk BM. Effectiveness of interventions to prevent obesity and obesity-related complications in children and adolescents. Pediatr Nurs. 2001;27(6):606-610. [pmid: 12024535].