# Appendix D. Search Strategies

Databases searched: Medline®, PsycINFO, DARE, CINAHL, Cochrane Database of Systematic Reviews, Cochrane Central Register of Controlled Trials

KQ 1 and KQ 2 Years searched: 1966-June 4, 2004

1 obesity/
2 obesity in diabetes/
3 obesity, morbid/
4 (obesity or obese).ti,ab.
5 overweight.ti,ab.
6 1 or 2 or 3 or 4 or 5
7 body mass index/
8 skinfold thickness/
9 Body Height/
10 body weight/
11 9 and 10
12 bmi.ti,ab.
13 body mass indices.ti,ab.
14 body mass index$.ti,ab.
15 skinfold.ti,ab.
16 skin fold.ti,ab.
17 weight for height.ti,ab.
18 height for weight.ti,ab.
19 weight for length.ti,ab.
20 weight for age.ti,ab.
21 weight for stature.ti,ab.
22 self report$.ti,ab.
23 parent$ report$.ti,ab.
24 patient report$.ti,ab.
25 screen$.ti,ab.
26 mass screening/
27 7 or 8 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26
28 6 and 27
29 obesity/di
30 obesity in diabetes/di
31 obesity, morbid/di
32 ((obesity or obese or overweight) adj5 diagnos$).ti,ab.
33 29 or 30 or 31 or 32
34 28 or 33
35 limit 34 to (preschool child <2 to 5 years> or child <6 to 12 years> or adolescent <13 to 18 years>)
36 child.ti,ab.
37 children$.ti,ab.
38 childhood.ti,ab.
39 preschool$.ti,ab.
40 teen.ti,ab.
41 teens.ti,ab.
42 teenage$.ti,ab.
43 pediatric$.ti,ab.
44 paediatric$.ti,ab.
45 adolescen$.ti,ab.
46 boys.ti,ab.
47 girls.ti,ab.
48 youth.ti,ab.
49 youths.ti,ab.
50 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49
51 34 and 50
52 35 or 51
53 limit 52 to english language
54 clinical trials/ or clinical trials, phase i/ or clinical trials, phase ii/ or clinical trials, phase iii/ or clinical trials, phase iv/ or controlled clinical trials/ or randomized controlled trials/ or multicenter studies/
55 research design/ or control groups/ or double-blind method/ or meta-analysis/
56 evaluation studies/ or program evaluation/
57 epidemiologic research design/ or control groups/ or cross-over studies/ or double-blind method/ or matched-pair analysis/ or meta-analysis/ or random allocation/ or “sensitivity and specificity”/ or predictive value of tests/ or roc curve/ or single-blind method/
58 PLACEBOS/
59 Comparative Study/
60 (clinical trial or clinical trial phase i or clinical trial phase ii or clinical trial phase iii or clinical trial phase iv or controlled clinical trial or meta analysis or multicenter study or randomized controlled trial).pt.
61 clinical trial$.ti,ab.
62 (control$ adj (trial$ or stud$ or evaluation$ or experiment$)).ti,ab.
63 ((singl$ or doubl$ or trebl$ or tripl$) adj5 (blind$ or mask$)).ti,ab.
64 placebo$.ti,ab.
65 random$.ti,ab.
66 evaluation stud$.ti,ab.
67 matched pair$.ti,ab.
68 control group$.ti,ab.
69 (outcome study or outcome studies).ti,ab.
70 (quasiexperimental or quasi experimental or pseudoexperimental or pseudo experimental).ti,ab.
71 (nonrandomi?ed or non randomi?ed or pseudorandomi?ed or pseudo randomi?ed).ti,ab.
72 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71
73 72 or random allocation/
74 epidemiologic studies/ or case-control studies/ or retrospective studies/ or cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ or cross-sectional studies/
75 (sensitivit$ or specificit$).ti,ab.
76 (meta analy$ or metaanaly$).ti,ab.
77 (systematic$ review$ or systematic$ overview$).ti,ab.
78 (quantitative$ review$ or quantitative$ overview$).ti,ab.
79 Evidence-Based Medicine/
80 evidence based review$.ti,ab.
81 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80
82 53 and 81
83 (comment or editorial or letter).pt.
84 case report/
85 83 or 84
86 82 not 85

KQ 3: Years searched: 1966-June 4, 2004

1 OBESITY/di
2 Obesity in Diabetes/di
3 Obesity, Morbid/di
4 (diagnos$ adj3 obes$).ti,ab.
5 (diagnos$ adj3 overweight).ti,ab.
6 (screen$ adj5 obes$).ti,ab.
7 (screen$ adj5 overweight).ti,ab.
8 1 or 2 or 3 or 4 or 5 or 6 or 7
9 limit 8 to (preschool child <2 to 5 years> or child <6 to 12 years> or adolescent <13 to 18 years>)
10 child.ti,ab.
11 children$.ti,ab.
12 childhood.ti,ab.
13 teen.ti,ab.
14 teens.ti,ab.
15 teenage$.ti,ab.
16 pediatric$.ti,ab.
17 paediatric$.ti,ab.
18 adolescen$.ti,ab.
19 boys.ti,ab.
20 girls.ti,ab.
21 youth.ti,ab.
22 youths.ti,ab.
23 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22
24 8 and 23
25 9 or 24
26 ae.fs.
27 advers$ effect$.ti,ab.
28 (harm or harms or harmed or harmful).ti,ab.
29 quality of life/
30 depression/
31 depressive disorder/
32 (depression or depressed).ti,ab.
33 stress, psychological/
34 adaptation, psychological/
35 anxiety/
36 (anxiety or anxious).ti,ab.
37 px.fs.
38 suicide/
39 self concept/
40 self esteem.ti,ab.
41 body image/
42 social isolation/
43 risk/
44 risk factors/
45 risky behavior$.ti,ab.
46 risky behaviour$.ti,ab.
47 risk taking/
48 Professional-Patient Relations/
49 Physician-Patient Relations/
50 Patient Compliance/
51 Patient Acceptance of Health Care/
52 Patient Participation/
53 Treatment Refusal/
54 Patient Dropouts/
55 eating disorders/
56 Anorexia Nervosa/
57 bulimia/
58 weight cycling.ti,ab.
59 weight fluctuat$.ti,ab.
60 fasting/
61 laxative$.ti,ab.
62 (overweight adj4 concern$).ti,ab.
63 (weight adj4 concern$).ti,ab.
64 family relations/
65 intergenerational relations/
66 parent-child relations/
67 parenting/
68 sibling relations/
69 family/
70 interpersonal relations/
71 False Positive Reactions/
72 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71
73 25 and 72
74 limit 73 to english language

KQ 4 and KQ 5: Years searched: 2001-June 4, 2004

1 exp “Obesity”/
2 “Weight-Gain”/
3 “Weight-Loss”/
4 (obesity or obese).mp.
5 (weight gain or weight loss).mp.
6 (overweight or over weight or overeat$ or over eat$).mp.
7 weight change$.mp.
8 ((bmi or body mass index) adj2 (gain or loss or change)).mp.
9 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8
10 limit 9 to child <6 to 12 years>
11 limit 9 to adolescent <13 to 18 years>
12 limit 9 to preschool child <2 to 5 years>
13 (child$ or adolescen$).mp.
14 (teenage$ or young people or young person or young adult$).mp.
15 (schoolchildren or school children).mp.
16 (pediatr$ or paediatr$).ti,ab.
17 (boys or girls or youth or youths).mp.
18 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17
19 exp “Behavior-Therapy”/
20 Social Support/
21 Family-Therapy/
22 exp “Psychotherapy-Group”/
23 ((psychological or behavio?r$) adj (therapy or modif$ or strateg$ or intervention$)).mp.
24 (group therapy or family therapy or cognitive therapy).mp.
25 ((lifestyle or life style) adj (chang$ or intervention$)).mp.
26 counsel?ing.mp.
27 social support.mp.
28 (peer adj2 support).mp.
29 ((children adj3 parent$) and therapy).mp.
30 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29
31 exp OBESITY/dt
32 exp Anti-Obesity Agents/
33 lipase inhibitor$.mp.
34 (orlistat or xenical or tetrahydrolipstatin).mp.
35 (appetite adj (suppressant$ or depressant$)).mp.
36 sibutramine.mp. or meridia.ti,ab.
37 (dexfenfluramine or fenfluramine or phentermine).mp.
38 bulking agent$.mp.
39 (methylcellulose or celevac).mp.
40 ((antiobesity or anti obesity) adj (drug$ or agent$)).mp.
41 guar gum.mp.
42 (metformin or glucophage).mp.
43 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42
44 exp OBESITY/dh
45 “Diet-Fat-Restricted”/
46 “Diet-Reducing”/
47 “Diet-Therapy”/
48 “Fasting”/
49 (diet or diets or dieting).mp.
50 (diet$ adj (modif$ or therapy or intervention$ or strateg$)).mp.
51 (low calorie or calorie control$ or healthy eating).mp.
52 (fasting or modified fast$).mp.
53 exp “Dietary-Fats”/
54 (fruit or vegetable$).mp.
55 (high fat$ or low fat$ or fatty food$).mp.
56 formula diet$.mp.
57 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56
58 “Exercise”/
59 “Exercise-Therapy”/
60 exercis$.mp.
61 (aerobics or physical therapy or physical activity or physical inactivity).mp.
62 (fitness adj (class$ or regime$ or program$)).mp.
63 (physical training or physical education).mp.
64 dance therapy.mp.
65 sedentary behavio?r reduction.mp.
66 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65
67 exp OBESITY/su
68 “Surgical-Staplers”/
69 “Surgical-Stapling”/
70 “Lipectomy”/
71 “Gastric-Bypass”/
72 “Gastroplasty”/
73 (dental splinting or jaw wiring).mp.
74 (gastroplasty or gastric band$ or gastric bypass).mp.
75 (intragastric balloon$ or vertical band$).mp.
76 (stomach adj (stapl$ or band$ or bypass)).mp.
77 liposuction.mp.
78 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77
79 exp “Alternative-Medicine”/
80 (alternative medicine or complementary therap$ or complementary medicine).mp.
81 (hypnotism or hypnosis or hypnotherapy).mp.
82 (acupuncture or homeopathy).mp.
83 (chinese medicine or indian medicine or herbal medicine or ayurvedic).mp.
84 79 or 80 or 81 or 82 or 83
85 ((diet or dieting or slim$) adj (club$ or organi?ation$)).mp. g]
86 (weightwatcheR$ or weight watcher$).mp.
87 (correspondence adj (course$ or program$)).mp.
88 (fat camp$ or diet$ camp$).mp.
89 85 or 86 or 87 or 88
90 (family intervention$ or parent$ intervention$).mp.
91 (parent$ adj2 (behavio?r or involve$ or control$ or attitude$ or educat$)).mp.
92 90 or 91
93 exp OBESITY/pc
94 secondary prevention.mp.
95 (preventive measure$ or preventative measure$).mp.
96 (preventive care or preventative care).mp.
97 (obesity adj2 (prevent$ or treat$)).mp.
98 93 or 94 or 95 or 96 or 97
99 (systematic$ review$ or systematic$ overview$).mp.
100 (quantitative$ review$ or quantitative$ overview$).mp.
101 Evidence-Based Medicine/
102 evidence based review$.mp.
103 exp “Controlled-Clinical-Trials”/
104 exp “Research-Design”/
105 ((singl$ or doubl$ or trebl$ or tripl$) adj5 (blind$ or mask$)).mp.
106 (CONTROLLED-CLINICAL-TRIAL or RANDOMIZED CONTROLLED TRIAL or META-ANALYSIS).pt.
107 (control$ and (trial$ or stud$ or evaluation$ or experiment$)).ti,ab.
108 (comparison group$ or control group$).mp.
109 matched pairs.mp.
110 (outcome study or outcome studies).mp.
111 (quasiexperimental or quasi experimental or pseudo experimental).mp.
112 (nonrandomi?ed or non randomi?ed or pseudo randomi?ed).mp.
113 99 or 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109 or 110 or 111 or 112
114 9 and 18
115 30 or 43 or 57 or 66 or 78 or 84 or 89 or 92 or 98
116 113 and 114 and 115
117 limit 116 to animals
118 limit 116 to human
119 117 not (117 and 118)
120 116 not 119
121 limit 120 to yr=2001-2004
122 limit 121 to english language

KQ 6: Years searched: 2001-June 4, 2004

1 obesity/
2 obesity in diabetes/
3 obesity, morbid/
4 (obesity or obese).ti,ab.
5 overweight.ti,ab.
6 1 or 2 or 3 or 4 or 5
7 child, preschool/
8 child/
9 adolescent/
10 7 or 8 or 9
11 6 and 10
12 obesity/th
13 obesity in diabetes/th
14 obesity, morbid/th
15 obesity/dt
16 obesity in diabetes/dt
17 obesity, morbid/dt
18 drug therapy.ti,ab.
19 exp anti-obesity agents/
20 (orlistat or xenical or tetrahydrolipstatin).mp.
21 (sibutramine or meridia in ti,ab).mp. [mp=title, abstract, name of substance, mesh subject heading]
22 (metformin or glucophage).mp.
23 (behavior$ therapy or behaviour$ therapy).ti,ab.
24 behavior therapy/
25 (fat camp$ or diet$ camp$).ti,ab.
26 (family intervention$ or parent$ intervention$).ti,ab.
27 ((lifestyle or life style) adj (chang$ or intervention$)).ti,ab.
28 obesity/dh
29 obesity, morbid/dh
30 obesity in diabetes/dh
31 (low calorie or calorie control$).ti,ab.
32 “Diet-Fat-Restricted”/
33 “Diet-Reducing”/
34 “Diet-Therapy”/
35 exercise/
36 physical activity.ti,ab.
37 sedentary behavio?r reduction.ti,ab.
38 obesity/su
39 obesity, morbid/su
40 obesity in diabetes/su
41 gastric bypass/
42 gastroplasty/
43 (gastroplasty or gastric band$ or gastric bypass).ti,ab.
44 weight loss intervention$.ti,ab.
45 diet$ intervention$.ti,ab.
46 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45
47 11 and 46
48 ae.fs.
49 adverse effect$.ti,ab.
50 (harm or harms or harmful or harmed).ti,ab.
51 (risky behavior$ or risky behaviour$).ti,ab.
52 to.fs.
53 weight gain/
54 (overeat$ or over$ eat$).ti,ab.
55 weight change$.ti,ab.
56 Weight regain.ti,ab.
57 weight cycling.ti,ab.
58 weight fluctuation$.ti,ab.
59 mo.fs.
60 Mortality/
61 Morbidity/)
62 Postoperative complications/
63 Postoperative complication$.ti,ab.
64 Survival rate/
65 Survival rate.ti,ab.
66 Reoperation/
67 Reoperation.ti,ab.
68 eating disorders/
69 Eating disorder$.ti,ab.
70 anorexia nervosa/
71 Anorexia nervosa.ti,ab.
72 bulimia/
73 Bulimi$.ti,ab.
74 Laxative$.ti,ab.
75 Binging.ti,ab.
76 Purging.ti,ab.
77 depression/
78 depressive disorder/
79 (depression or depressed).ti,ab.
80 anxiety/
81 (anxiety or anxious).ti,ab.
82 suicide/
83 Suicid$.ti,ab.
84 body image/
85 Body image.ti,ab.
86 self esteem.ti,ab.
87 Self concept/
88 quality of life/
89 Quality of life.ti,ab.
90 in.fs.
91 Athletic injuries/
92 School functioning.ti,ab.
93 (Behavior$ problems or behaviour$ problems).ti,ab. (4405)
94 (Growth impairment or Growth retardation or Growth failure or impaired growth).ti,ab. (12511)
95 Growth disorders/ (10322)
96 (linear growth and (stunt$ or retard$)).ti,ab. (235)
97 Growth spurt$.ti,ab. (1096)
98 (Secondary amenorrhea or secondary amenorrhoea).ti,ab. (956)
99 or/48–98 (1816670)
100 47 and 99 (1194)
101 limit 100 to english language (1009)
102 limit 101 to human (1009)