# Appendix C. Clinical Measures of Overweight

The limitations of the clinically feasible adiposity measures in children necessitate adopting different measures for obesity diagnosis. Height and weight measures are simple, practical, and reliable. ^1^ Their use to estimate overweight has traditionally involved classifying children by percentage deviation from mean weight or weight-for-height on age-standardized growth charts. ^2^ Weight must be adjusted for height to reflect age-normal differences in growth and body build. Measures of weight per height include weight/height; weight/height ^2^ (body mass index [BMI] or Quetelet index); weight/height ^3^ (ponderal index); weight/height^k^ ; standardized weight (measured weight minus mean weight for that height divided by standard deviation of weight for that height); and relative weight (weight X 100 /mean weight for that height). ^3^ An important limitation of all weight-for-height measures is that they cannot distinguish between excess weight due to increased adiposity from that due to increased lean body mass. Thus, use of these measures defines obesity as excess body weight rather than excess body fat.

Among the many weight-for-height adjusted measures, BMI has become the primary index of relative weight. ^4^ BMI equals kilograms of weight divided by height in meters squared (kg/m^2^), and is compared to population-based reference standards. In 1997, a workshop to assess the strengths and limitations of practical measurements to assess overweight and obesity in children and adolescents worldwide was convened by the International Obesity Task Force. ^5^ In reviewing the use of BMI, other weight-for-height indicators, and indirect measures of body fat, experts concluded that BMI offered a reasonable measure of fatness in children and adolescents. They based their conclusion on moderate to high correlations (.44–.82) between BMI and percentage body fat (measured by DEXA or by underwater weighing) in non-obese boys and girls aged 4–18 years, and the lack of reproducibility of direct measures of body fat, such as triceps skinfolds. Further, the authors noted that use of BMI in children and adolescents would provide a consistent assessment of obesity across the lifespan. However, they also noted several problems with the use of BMI as an adiposity index, including the fact that although BMI is highly correlated with measures of body fat, it is not a precise indicator of overweight or obesity, since high BMI for an individual child or adult can be due to increased fat-free mass. ^6^ This concern has been amplified in a study in which a large proportion of the between-child variations in BMI were explained by variability in fat-free mass and not just differences in fat mass. ^7^ Also, there is limited data on BMI's appropriateness in non-white ethnic groups. Among black and white nine-year-old girls in the National Heart, Lung and Blood Institute Growth and Health study, BMIs are consistently higher in black girls of all ages. ^8^ This does not necessarily reflect overall greater adiposity among black females, since across these ages the BMIs of black girls in the 15^th^ percentile by race consistently exceed those of white girls in the 15^th^ percentile by 0.5 kg/m^2^. In a cross-sectional study of 192 healthy boys and girls aged 7–17 years old (46% black and 54% white), the relationship between BMI and percentage body fat measured by DEXA was dependent on several factors in addition to the known differences due to sex ^9^ : sexual maturation (body fat is lower in those of greater sexual maturity), race (at a given BMI, whites have higher body fat than blacks), and waist: hip ratio (at the same BMI, higher ratios are associated with greater body fatness). Stage of sexual maturation was a more important correlate of percent body fat than age; thus, the percent body fat for a given BMI may differ depending on the level of maturation.

Another concern about BMI as a measure of fatness in individual children comes from reliance on strength of correlation rather than calculated agreement between methods in determining the validity of BMI. ^10^

Although a number of studies have found that BMI cutoffs at the upper end of the distribution are reasonably specific for classifying the fattest children, ^11^ this body of literature is comprised of studies using different BMI cutoff definitions and varying criterion measures of body fat, many of which are not directly comparable or are of questionable validity. ^12^ – ^14^ (See Appendix B, Table B-1) There is little evidence on the sensitivity and specificity of BMI as a screening tool for obesity compared to valid reference standards in large U.S. samples of boys and girls of all ages and races, with the body composition range from low to the excess adiposity seen in clinical practice. For example, in a study of 1,570 children aged 9–19 years of BMI validity in obesity, triceps skinfold (TSF) was the fat criterion used for most of the sample; as a reference criterion TSF is insufficient. ^15^ Among the remainder of the sample with a valid fat criterion measure (98 Mexican American boys and 104 white girls), none had BMI measures at or above the 95^th^ percentile. BMI at the 85^th^ percentile was reasonably specific in boys (98.8%) and girls (95.0%) but very insensitive (values of 30.8% or less). Studies such as these are inadequate to answer how validly BMI identifies excess fat. Given the current state of this literature on BMI, many have shifted their focus to the validity of BMI cutpoints as a pragmatic measure of risk for adult overweight and as an indicator of future morbidity or mortality. ^16,^ ^17^

Measures other than BMI, such as skinfold thicknesses and waist circumference, are not sufficiently well-developed in terms of reference values, measurement approaches, or established relationships to criterion methods or to morbid outcomes to serve as independent clinical measures. ^18^ Other clinical measures such as these may eventually prove useful in supplementing BMI to define overweight in particular subgroups, such as adolescent males. ^13^

## References for Appendix C

1 Kuczmarski RJ. Trends in body composition for infants and children in the U.S. Crit Rev Food Sci Nutr. 1993;33(45):375-387. [pmid: 8357500].
2 Oken E, Lightdale JR. Updates in pediatric nutrition. Curr Opin Pediatr. 2000;12(3):282-290. [pmid: 10836167].
3 Thomas PW, Peters TJ, Golding J, Haslum MN. Weight-for-height in two national cohorts with particular reference to 10-year-old children. Annals of Human Biology. 1989;16(2):109-119. [pmid: 2729888].
4 Poskitt EM. Defining childhood obesity: the relative body mass index (BMI). European Childhood Obesity group. Acta Paediatr. 1995;84(8):961-963. [pmid: 7488831].
5 Dietz WH, Bellizzi MC. Introduction: the use of body mass index to assess obesity in children. Am J Clin Nutr. 1999;70(1):123S-125S. [pmid: 10419414].
6 Maynard LM, Wisemandle W, Roche AF, Chumlea WC, Guo SS, Siervogel RM. Childhood body composition in relation to body mass index. Pediatrics. 2001;107(2):344-350. [pmid: 11158468].
7 Wells JC. A Hattori chart analysis of body mass index in infants and children. Int J Obes Relat Metab Disord. 2000;24(3):325-329. [pmid: 10757626].
8 Kimm SY, Barton BA, Obarzanek E, McMahon RP, Sabry ZI, Waclawiw MA, et al. Racial divergence in adiposity during adolescence: The NHLBI Growth and Health Study. Pediatrics. 2001;107(3):E34. [pmid: 11230615].
9 Daniels SR, Khoury PR, Morrison JA. The utility of body mass index as a measure of body fatness in children and adolescents: differences by race and gender. Pediatrics. 1997;99(6):804-807. [pmid: 9164773].
10 Reilly JJ. Assessment of body composition in infants and children. Nutrition. 1998;14(10):821-825. [pmid: 9785371].
11 Reilly JJ, Wilson ML, Summerbell CD, Wilson DC. Obesity: diagnosis, prevention, and treatment; evidence based answers to common questions. Arch Dis Child. 2002;86(6):392-394. [pmid: 12023163]. [pmcid: 1762983].
12 Ellis KJ. Human body composition: in vivo methods. Physiol Rev. 2000;80(2):649-680. [pmid: 10747204].
13 Himes JH. Agreement among anthropometric indicators identifying the fattest adolescents. Int J Obes Relat Metab Disord. 1999;23(Suppl 2):S18-S21. [pmid: 10340800].
14 Wells JC, Fuller NJ, Dewit O, Fewtrell MS, Elia M, Cole TJ. Four-component model of body composition in children: density and hydration of fat-free mass and comparison with simpler models. Am J Clin Nutr. 1999;69(5):904-912. [pmid: 10232629].
15 Malina RM, Katzmarzyk PT. Validity of the body mass index as an indicator of the risk and presence of overweight in adolescents. Am J Clin Nutr. 1999;70(1):131S-136S.
16 Reilly JJ, Methven E, McDowell ZC, Hacking B, Alexander D, Stewart L, et al. Health consequences of obesity. Arch Dis Child. 2003;88(9):748-752. [pmid: 12937090]. [pmcid: 1719633].
17 Dietz WH. Childhood weight affects adult morbidity and mortality. Journal of Nutrition. 1998;128(2 Suppl):411S-414S. [pmid: 9478038].
18 Lobstein T, Baur L, Uauy R. Obesity in children and young people: a crisis in public health. Obes Rev. 2004;5(Suppl 1):4-85. [pmid: 15096099].