# Appendix B. Measuring Adiposity in Children and Adolescents

In this section, we review the challenges in measuring adiposity through direct or indirect measurements of body composition, since these challenges directly affect the choice of appropriate and available clinical measurement techniques, and determine the acceptability of reference standards used to validate clinical measures in screening and intervention (Table B-1). We then examine the advantages and limitations of clinical measures of overweight, such as body mass index (BMI).

## Measures of Adiposity

In obesity, adiposity (total body fat expressed as a percentage of total body weight) is the body composition measure of primary physiologic interest. ^1^ Body fat mass (FM) measurement through direct or indirect approaches is preferable, but not practical for routine use. FM is one of two main components of body composition, along with fat-free mass (FFM)—which can be further divided into subcompartments of total body water, body protein, and body mineral. ^2,^ ^3^ Body composition is measured directly using dual x-ray absorptiometry (DEXA) or hydrodensitometry, with FM determined from this measurement in combination with measured results for other body components. ^4^ Body composition must be measured and not inferred as its components change with growth and development throughout childhood and adolescence, with expected variations due to sex, age, pubertal status, race/ethnicity, athletic status, and disease state. ^3,^ ^5,^ ^6^ Laboratory-based body composition approaches that directly measure multiple (three or more) body compartments are accepted as valid for estimating body fat in children, ^7,^ ^8^ particularly after age three-five when hydration levels of fat-free mass reach adult values. ^3^ Multicomponent body composition measures offer greater accuracy and precision in children ^7^ but are not practical for clinical practice or large-scale epidemiologic surveys on the basis of cost, portability, and acceptability to the patient. ^8^

## Clinical Measures of Total Body Adiposity

Portable, non-invasive measures of body fat appropriate for clinical practice, such as skinfold thickness (SKF) and, more recently, bioelectrical impedance analysis (BIA), are proxy (indirect) measures for determining total body fat. These measures are used in prediction equations to estimate a simpler two-component model of body composition—FM and FFM—in order to determine whether there is excess fat (obesity). The two-component body composition model is increasingly recognized as insufficient for estimating body fat in children, because the subcomponents of FFM in children are not constant as they generally are in adults. Children and prepubescent adolescents exhibit chemical immaturity, ^6^ with a gradual change in FFM composition through infancy, childhood, and adolescence to adult values. ^8^

The two-component model is based on assumptions that ignore other sources of interindividual variability in the composition of FFM in children, such as variations in bone mineral content due to race/ethnicity. ^9^ In 20 black and 20 white normal-weight girls aged 7–10 years who were matched for BMI, bone age, chronological age, Tanner breast stage, and socioeconomic status, black girls had significantly greater bone mineral density and less total adipose tissue than white girls. ^10^ This finding of increased bone mineral content in prepubescent black girls, compared with age- and weight-matched white girls, has been confirmed in other studies. Ethnic differences in skeletal growth patterns, as well as effects of puberty on bone density, have also been reported. ^9^

Prediction equations used to determine body fat from anthropometric measurements in two-component or other models are problematic. These equations have often been derived from samples including a wide range of prepubescent, pubescent, and postpubescent subjects, and therefore do not apply well to any of these subgroups, as each group differs in the relationship between skinfold thickness and body density. ^6^ Equations developed to predict body fat based on BIA tend to lack cross-validity even when they have been “validated,” (i.e., they do not provide accurate estimates in populations other than those in which they were derived). ^8^ Different prediction equations in the same children result in very different estimates of mean body fat: estimates range from 5.0 percentage points below to 3.0 points above the reference method for prediction equations based on skinfold measurements, and from 6.8 percentage points below to 8.6 points above for prediction equations based on BIA measurements. ^8^ The ability of BIA to predict body composition in children varies by equation, and its accuracy cannot be safely assumed. ^11^ Few prediction equations based on BIA measurements have been rigorously evaluated in obese persons. ^12^ Finally, few prediction equations have been validated in people of diverse racial backgrounds, ^6^ although some reports are appearing.

Indirect measures of body fat often have additional measurement limitations due to variation in the selection of sites and in measurement techniques. ^6^ In some circumstances the assessment of body composition by such measures is compromised more by measurement variability than by overall inaccuracy. ^13^ Skinfold measurements with a single observer can be reproducible, ^12^ but interrater reliability is often poor. ^14,^ ^15^ ^16^ Skinfold measures are even less reliable for those with markedly increased body fat. ^17^ Instruments under development that may have future clinical application in pediatric body composition measurement, such as air-displacement plethysmography and bioelectrical impedance, still show considerable variability between instruments and methods. ^3,^ ^18,^ ^19^

## Clinical Measures of Intra-Abdominal Adiposity

In adults, intra-abdominal body fat (around visceral organs) is related to negative health outcomes independent of total body fat. ^4,^ ^20^ Intra-abdominal fat as measured anthropometrically in children and adolescents has been related cross-sectionally to presence and clustering of cardiovascular risk factors within black and white children. ^21^ – ^23^ Research in this area is active. It is currently unclear whether and when visceral fat accumulates in children as an appropriate part of growth and development. Intra-abdominal adipose tissue has been observed in healthy, non-obese children as young as four-seven years of age, as well as non-obese adolescents. ^4^ Waist circumference correlates most strongly with DEXA-determined fat distribution in 201 black and white children aged 7–17 years, compared with other indirect measures of intra-abdominal obesity including BMI, waist-hip circumference ratio, subscapular/triceps skinfold ratio, and subscapular + suprailiac/triceps skinfold ratio. ^24^ However, in studies using more accurate imaging techniques for assessing body fat distribution in children (CT and MRI), neither waist circumference nor other indirect indicators of body fat distribution correlate well with intra-abdominal adipose tissue. ^4^ Given the uncertainties about the clinical meaning of indirect central obesity measures, including the extent of normal variations due to age, gender, race, and percentage body fat ^4,^ ^24^ and whether observed extremes in these measures have an impact on current and future morbidity, ^25^ these tools are not appropriate for clinical obesity screening at this time.

## Comparability of Clinical Measures for Adiposity

Even if acceptable, clinical measures for adiposity cannot be assumed to substitute for one another. Several recent studies illustrate the current limits of utility and consistency between various clinical adiposity measures in children. Researchers categorized 625 overweight and obese white youths aged 12–18 years in the NHANES III study as obese if they were above the 80^th^ percentile in their age and-sex group for BMI, triceps and subscapular skinfolds, sum of four skinfolds, waist circumference, or percentage body fat determined by BIA. ^26^ Agreement between the anthropometric methods for overweight categorization ranged from kappas of 0.065–0.85 in males and 0.050–0.79 in females, and showed further within-sex variation by age. The overall agreement between waist circumference and percent body fat was the lowest of the tested measures. When SKF measures were compared to a four-component criterion model for 40 African American and 72 white adolescent girls, individual percent fat mass could be over- or under-estimated by as much as 10%. ^27^ Racial/ethnic subgroups may need separate reference standards. Important age, sex, and ethnic differences in body fat growth have been described, when comparing percent body fat growth estimates from two different sum of skinfold measures and those from bioelectrical impedance combined with body measurements, body mass index, and abdominal circumference in 678 boys and girls (20% black, 75% non-Hispanic white, and 5% other). ^28^ Fat growth patterns showed marked differences for each index, and within indices, varied by sex, age, and race/ethnicity. For three measures (percent body fat, sum of two skinfolds, and sum of six skinfolds), black females had the highest values, followed by non-black females and non-black males, with lowest values among black males. However, the shapes of the curves were not comparable either within or across measures. The authors point out that the distinct growth patterns for different indices of body fat indicate that they likely measure different tissue content, and thus should not be expected to relate in the same way to intermediate or actual health outcomes.

Table B1 Reference Standards for Pediatric Obesity Screening ^2,^ ^3,^ ^6,^ ^8,^ ^12,^ ^17,^ ^19,^ ^29^ – ^37^

[underlined: Preferable/Highest validity]
4-C model (independent measurement of bone mineral content, TBW, and NAA measurement or extrapolation of body protein from bone mineral measurement)
3-C model at age five or above (independent measurement of TBW via isotope dilution and body density via BODPOD, isotope dilution, or hydrodensitometry using Lohman's equations) (except in racial and ethnic subgroups or athletes, then becomes only acceptable)
[underlined: Acceptable]
3-C model at age five or above (independent measurement of TBW via isotope dilution and FFM from total body potassium)
3-C model (independent measurement of TBW via means other than isotope dilution (e.g., TOBEC) and body density via BODPOD, isotope dilution, or hydrodensitometry not clearly using Lohman's equations)
3-C model (independent measurement of bone mineral content via DEXA and hydrodensitometry using Lohman's equations)
DEXA alone in a 3C model (used to measure BMC, lean tissue mass to derive fat mass)
[underlined: Barely acceptable]
2-C model at age five or above (measurement of TBW via isotope dilution)
2-C model using Lohman's equation or equivalent
[underlined: Unacceptable]
MRI (due to cost, duration of testing)
Whole body CT (due to cost, radiation exposure)
Bioelectrical impedance (BIA)-potential screening test
Electromagnetic induction alone or in children under five(e.g., TOBEC)
2-C model not using Lohman's age and sex-specific equations
2-C model, measurement of total body K+
-Near infrared interactance (NIRI)
-Skinfold thickness, other anthropomorphic measures

### References for Appendix B

1 Oken E, Lightdale JR. Updates in pediatric nutrition. Curr Opin Pediatr. 2000;12(3):282-290. [pmid: 10836167].
2 Sutcliffe JF. A review of in vivo experimental methods to determine the composition of the human body. Phys Med Biol. 1996;41(5):791-833. [pmid: 8735251].
3 Ellis KJ. Human body composition: in vivo methods. Physiol Rev. 2000;80(2):649-680. [pmid: 10747204].
4 Goran MI. Measurement issues related to studies of childhood obesity: assessment of body composition, body fat distribution, physical activity, and food intake. Pediatrics. 1998;101(3 Pt 2):505-518. [pmid: 12224657].
5 Lohman T. Advances in Body Composition Assessment. 3rd ed. Champaign, IL: Human Kinetics Publishers, 1992.
6 Lohman TG. Applicability of body composition techniques and constants for children and youths. Exerc Sport Sci Rev. 1986;14:325-357. [pmid: 3525188].
7 Wells JC, Fuller NJ, Dewit O, Fewtrell MS, Elia M, Cole TJ. Four-component model of body composition in children: density and hydration of fat-free mass and comparison with simpler models. Am J Clin Nutr. 1999;69(5):904-912. [pmid: 10232629].
8 Reilly JJ. Assessment of body composition in infants and children. Nutrition. 1998;14(10):821-825. [pmid: 9785371].
9 Gasperino J. Ethnic differences in body composition and their relation to health and disease in women. Ethnicity & Health. 1996;1(4):337-347. [pmid: 9395578].
10 Yanovski JA, Yanovski SZ, Filmer KM, Hubbard VS, Avila N, Lewis B, et al. Differences in body composition of black and white girls. American Journal of Clinical Nutrition. 1996;64(6):833-839. [pmid: 8942404].
11 Reilly JJ, Wilson J, McColl JH, Carmichael M, Durnin JV. Ability of biolectric impedance to predict fat-free mass in prepubertal children. Pediatr Res. 1996;39(1):176-179. [pmid: 8825406].
12 Jebb SA, Elia M. Techniques for the measurement of body composition: a practical guide. Int J Obes Relat Metab Disord. 1993;17(11):611-621. [pmid: 8281219].
13 Elia M. Body composition analysis: an evaluation of 2 component models, multicomponent models and bedside techniques. Clinical Nutrition. 1992;11:114-127. [pmid: 16839986].
14 Marks GC, Habicht JP, Mueller WH. Reliability, dependability, and precision of anthropometric measurements. The Second National Health and Nutrition Examination Survey 1976-1980. Am J Epidemiol. 1989;130(3):578-587. [pmid: 2764002].
15 Chumlea WC, Guo SS, Kuczmarski RJ, Flegal KM, Johnson CL, Heymsfield SB, et al. Body composition estimates from NHANES III bioelectrical impedance data. International Journal of Obesity & Related Metabolic Disorders. 2002;26(12):1596-1609. [pmid: 12461676].
16 Dietz WH, Bellizzi MC. Introduction: the use of body mass index to assess obesity in children. Am J Clin Nutr. 1999;70(1):123S-125S. [pmid: 10419414].
17 Kuczmarski RJ. Trends in body composition for infants and children in the U.S. Crit Rev Food Sci Nutr. 1993;33(45):375-387. [pmid: 8357500].
18 Fields DA, Goran MI, McCrory MA. Body-composition assessment via air-displacement plethysmography in adults and children: a review. Am J Clin Nutr. 2002;75(3):453-467. [pmid: 11864850].
19 Horlick M, Arpadi SM, Bethel J, Wang J, Moye J Jr, Cuff P, et al. Bioelectrical impedance analysis models for prediction of total body water and fat-free mass in healthy and HIV-infected children and adolescents. Am J Clin Nutr. 2002;76(5):991-999. [pmid: 12399270].
20 Bjorntorp P. Abdominal obesity and the metabolic syndrome. Ann Med. 1992;24(6):465-468. [pmid: 1485940].
21 Morrison JA, Barton BA, Biro FM, Daniels SR, Sprecher DL. Overweight, fat patterning, and cardiovascular disease risk factors in black and white boys. Journal of Pediatrics. 1999;135(4):451-457. [pmid: 10518096].
22 Morrison JA, Sprecher DL, Barton BA, Waclawiw MA, Daniels SR. Overweight, fat patterning, and cardiovascular disease risk factors in black and white girls: The National Heart, Lung, and Blood Institute Growth and Health Study. Journal of Pediatrics. 1999;135(4):458-464. [pmid: 10518079].
23 Freedman DS, Serdula MK, Srinivasan SR, Berenson GS. Relation of circumferences and skinfold thicknesses to lipid and insulin concentrations in children and adolescents: the Bogalusa Heart Study. Am J Clin Nutr. 1999;69(2):308-317. [pmid: 9989697].
24 Daniels SR, Khoury PR, Morrison JA. Utility of different measures of body fat distribution in children and adolescents. Am J Epidemiol. 2000;152(12):1179-1184. [pmid: 11130624].
25 McCarthy HD, Ellis SM, Cole TJ. Central overweight and obesity in British youth aged 11–16 years: cross sectional surveys of waist circumference. BMJ. 2003;326(7390):624. [pmid: 12649234]. [pmcid: 151972].
26 Himes JH. Agreement among anthropometric indicators identifying the fattest adolescents. Int J Obes Relat Metab Disord. 1999;23(Suppl 2):S18-S21. [pmid: 10340800].
27 Wong WW, Stuff JE, Butte NF, Smith EO, Ellis KJ. Estimating body fat in African American and white adolescent girls: a comparison of skinfold-thickness equations with a 4-compartment criterion model. American Journal of Clinical Nutrition. 2000;72(2):348-354. [pmid: 10919926].
28 Dai S, Labarthe DR, Grunbaum JA, Harrist RB, Mueller WH. Longitudinal analysis of changes in indices of obesity from age 8 years to age 18 years. Project HeartBeat!. American Journal of Epidemiology. 2002;156(8):720-729. [pmid: 12370160].
29 Ellis KJ. Measuring body fatness in children and young adults: comparison of bioelectric impedance analysis, total body electrical conductivity, and dual-energy X-ray absorptiometry. Int J Obes Relat Metab Disord. 1996;20(9):866-873. [pmid: 8880356].
30 Fomom SJ, Haschke F, Ziegler EE, Nelson SE. Body composition of reference children from birth to age 10 years. Am J Clin Nutr. 1982;35(5 Suppl):1169-1175. [pmid: 7081099].
31 Gately PJ, Radley D, Cooke CB, Carroll S, Oldroyd B, Truscott JG, et al. Comparison of body composition methods in overweight and obese children. J Appl Physiol. 2003;95(5):2039-2046. [pmid: 14555670].
32 Gutin B, Litaker M, Islam S, Manos T, Smith C, Treiber F. Body-composition measurement in 9–11-y-old children by dual-energy X-ray absorptiometry, skinfold-thickness measurements, and bioimpedance analysis. Am J Clin Nutr. 1996;63(3):287-292. [pmid: 8602582].
33 Houtkooper LB, Going SB, Lohman TG, Roche AF, Van Loan M. Bioelectrical impedance estimation of fat-free body mass in children and youth: a cross-validation study. J Appl Physiol. 1992;72(1):366-373. [pmid: 1537738].
34 Laskey MA. Dual-energy X-ray absorptiometry and body composition. Nutrition. 1996;12(1):45-51. [pmid: 8838836].
35 Treuth MS, Butte NF, Wong WW, Ellis KJ. Body composition in prepubertal girls: comparison of six methods. Int J Obes Relat Metab Disord. 2001;25(9):1352-1359. [pmid: 11571599].
36 Parker L, Reilly JJ, Slater C, Wells JC, Pitsiladis Y. Validity of six field and laboratory methods for measurement of body composition in boys. Obes Res. 2003;11(7):852-858. [pmid: 12855754].
37 Roemmich JN, Clark PA, Weltman A, Rogol AD. Alterations in growth and body composition during puberty. I. Comparing multicompartment body composition models. J Appl Physiol. 1997;83(3):927-935. [pmid: 9292482].