# Appendix S. Expert Reviewers

- Laurie Anderson, PhD
- Guide to Community Preventive Services
- Centers for Disease Control and Prevention

- Bill Dietz, MD, MPH
- Division of Nutrition and Physical Activity
- National Center for Chronic Disease Prevention and Health Promotion
- Centers for Disease Control and Prevention

- Robert Jeffrey, PhD
- Epidemiology
- University of Minnesota Twin Cities

- David Katz, MD, MPH, Director
- Yale-Griffin Prevention Research Center

- John J Reilly, PhD
- Reader in Paediatric Energy Metabolism,
- University of Glasgow
- Division of Developmental Medicine,
- Royal Hospital for Sick Children

- Thomas N. Robinson, MD, MPH
- Associate Professor of Pediatrics and of Medicine
- Division of General Pediatrics and
- Stanford Prevention Research Center
- Stanford University School of Medicine

- Carolyn Summerbell, PhD, RD
- Reader in Human Nutrition
- School of Health and Social Care
- University of Teesside