# Appendix R. Population-Based Obesity Prevalence Surveys

Survey | Dates | Age/years | Race/Ethnicity | Measures
NHES I | 1960-62 | 18–79 | Predominately white | Unable to locate
NHES II | 1963-65 | 6–11 | 14% black | wt=lbs; ht=cm Skinfold (3)
NHES III | 1966-70 | 12–17 | 10% black | wt=lbs; ht=cm Skinfold (4)
NHANES I | 1971-74 | 1–74 | *Race recorded as b, w, other | wt=lbs; ht=cm & in Skinfold (2)
**NHANES II | 1976-80 | 6 mos-74 | *Race recorded as b, w, other | wt=lbs; ht=cm & in Skinfold (2)
HHANES | 1982-84 | 6 mos-74 | Predominately Hispanic from SW USA | wt=lbs; ht=cm & in
NHANES III | 1988-94 | 2 mos + | ***Over sampled MA, NHB | wt = kg, ht=cm Skinfold (4)
NHANES | 1999-2000 | Birth + | ***Over sampled preschool age, MA, NHB | BIA, DEXA, ht, wt, Skinfold (1)

* Observed race recorded.

** Self-reported Hispanic origin.

*** Race self-reported as NHW, NHB, MA, Other.

## References for Appendix R

1 Plan and Operation of the Second National Health and Nutrition Examination Survey, 1976-1980. Series 1 ed. Hyattsville: U.S. Department of Health and Human Services Public Health Service, Office of Health Research, Statistics, and Technology, National Center for Health Statistics, 1981.
2 Plan and Operation of a Health Examination Survey of U.S. Youths 12–17 Years of Age. Series 1 ed. Rockville: U.S. Department of Health, Education, and Welfare, Public Health Service, National Center for Health Statistics, 1974.
3 Plan and Operation of the Health and Nutrition Examination Survey, United States 1971-1973. Series 1 ed. Hyattsville: U.S. Department of Health, Education, and Welfare, Public Health Service, Office of Health Research, Statistics, and Technology, National Center for Health Statistics, 1973.
4 Plan, Operation, and Response Results of a Program of Children's Examinations. Series 1 ed. Washington, D.C.: U.S. Department of Health, Education, and Welfare, Public Health Service, National Center for Health Statistics, 1967.
5 Plan and Initial Program of the Health Examination Survey. Series 1 ed. Washington, D.C.: U.S. Department of Health, Education, and Welfare, Public Health Service, National Center for Health Statistics, 1965.
6 Flegal KM, Carroll MD, Kuczmarski RJ, Johnson CL. Overweight and obesity in the United States: prevalence and trends, 1960-1994. Int J Obes Relat Metab Disord. 1998;22(1):39-47. [pmid: 9481598].
7 Troiano RP, Flegal KM, Kuczmarski RJ, Campbell SM, Johnson CL. Overweight prevalence and trends for children and adolescents. The National Health and Nutrition Examination Surveys, 1963 to 1991. Archives of Pediatrics & Adolescent Medicine. 1995;149(10):1085-1091. [pmid: 7550810].
8 Killeen J, Vanderburg D, Harlan WR. Application of weight-height ratios and body indices to juvenile populations—the National Health Examination Survey Data. J Chronic Dis. 1978;31(8):529-537. [pmid: 711845].