# Appendix Q. Outcomes Table Modeling Potentially Prevented Adult Cases of Disease by Screening 1,000 Adolescents and Treating Overweight Adolescents ( ≥95^th^ Percentile)

Using established cutpoints for overweight (≥ 95^th^ percentile) in adolescents, the group with the highest probability of developing adult overweight or obesity, we modeled the number needed to screen (NNS) to prevent one excess case of adult morbidity associated with overweight. We used nationally representative prevalence figures ^1^ for Mexican Americans and non-Hispanic blacks and whites, and a large population-based study for Native Americans. ^2^ We assumed screening 1,000 adolescents of the same sex and race in a clinic setting would yield these proportions. To model the risk of health conditions, we used sex-specific disease prevalence estimates attributable to severity of overweight and obesity from cross-sectional nationally representative data (NHANES III). ^3^ For the prevalence of disease associated with adult obesity, we chose the lowest estimates (associated with Obesity Class I (BMI) rather than Classes II or III) to avoid overestimating the excess cases associated with adult obesity. Based on the assumptions used to produce this outcomes table, we assumed that weight-related disease estimates applied equally across racial and ethnic minorities. We also assumed that the probability of adult disease in those initially overweight but achieving and maintaining a non-overweight BMI would equal that of adolescents at the non-overweight BMI initially. In the absence of adequate treatment data, we assumed that a low (0.10) or moderate (0.30) proportion of adolescents would respond to treatment by reducing and maintaining their BMI at normal adult levels (18.5 to 24.9).

Considering all cases of disease as occurring in different people and as of equal morbidity importance, there was a low of 18 excess cases of disease (diabetes mellitus II, gallbladder disease, coronary heart disease, osteoarthritis) due to adolescent overweight in adult non-Hispanic white males and a high of 58 excess cases in adult non-Hispanic black females. Similarly, there was a low of 38 excess cases with increased cardiovascular (CV) risk factors due to adult obesity or overweight in non-Hispanic white males and a high of 87 in non-Hispanic black females. The NNS varies with the presumed efficacy of treatment. If all patients enroll in treatment, and treatment is effective in 30% of participants, the NNS to prevent one adult case of disease ranges from a low of 59 in non-Hispanic black females to a high of 200 in non-Hispanic white males. If treatment is 10% effective, the NNS to prevent one case of adult disease ranges from a low of 200 in non-Hispanic black females to a high of 1,000 in non-Hispanic white males. No groups have an NNS of 100 or below for a treatment that returns 10% of overweight adolescent patients to normal weight. For a treatment that returns 30% of overweight adolescent patients to normal weight, four groups have an NNS of 100 or below: non-Hispanic black females (59), Mexican American females (77), Mexican American males (91), and Native American males (100). NNSs are more favorable when considering prevented CV risk factors or when combining diseases and risk factors. The number needed to treat (NNT) for both estimated levels of treatment efficacy are also reported.

We examined the proportion of the total disease or risk factor burden potentially prevented by screening and treating overweight adolescents by dividing the excess cases due to overweight that would be prevented with a low (0.10) or moderate (0.30) treatment regimen by the total burden of adult disease in all weight categories. One to five percent of the overall disease burden could be prevented through this approach, with similar proportions of the overall risk factor burden.

Using an outcomes table approach, we modeled the impact on adult weight-associated morbidities of identification and treatment of overweight adolescents based on BMI measurements (with 100% accuracy). For the treatment effect that seems most reasonable given the limited existing evidence (0.10 long-term treatment benefit), NNS is greater than 100 for all subgroups of adolescents. If a more robust sustained treatment effect could be sustained (0.30), then non-Hispanic black females, Mexican American males and females, and Native American males would all have an NNS of 100 or less. However, looked at a different way, the proportion of the overall disease prevented would be quite small (1%–7%), probably reflecting the fact that despite relatively strong tracking of adolescent overweight to adult obesity, most adults (75%) who are obese were not overweight as children. ^4^

Table Q-1 Outcomes Table Modeling Potentially Prevented Adult Cases of Disease by Screening 1,000 Adolescents and Treating Overweight Adolescents ( ≥ 95^th^ Percentile)

| | Mexican American | | | | Non-Hispanic Black | | | | Native American | | | | Non-Hispanic White
| | Males | | Females | | Males | | Females | | Males | | Females | | Males | | Females
Age | | 12 thru 19 | | | | 12 thru 19 | | | | 17 | | | | 12 thru 19
Prev/1000 ≥95th percentile ^1,^ ^2^ | | 275 | | 194 | | 207 | | 266 | | 259 | | 143 | | 128 | | 124
Adult BMI | | 25–29.9 | ≥30 | 25–29.9 | ≥30 | 25–29.9 | ≥30 | 25–29.9 | ≥30 | 25–29.9 | ≥30 | 25–29.9 | ≥30 | 25–29.9 | >30 | 25–29.9 | ≥30
Prob Adult Over-weight or Obesity ^5^ | | 0.2 | 0.8 | 0.3 | 0.7 | 0.2 | 0.8 | 0.3 | 0.7 | 0.2 | 0.8 | 0.3 | 0.7 | 0.2 | 0.77 | 0.3 | 0.7
Excess Adult Cases Due to Overweight or Obesity ^3^ | DMII | 19 | | 9 | | 14 | | 12 | | 18 | | 7 | | 9 | | 6
| GBD | 8 | | 16 | | 6 | | 22 | | 8 | | 12 | | 4 | | 10
| CHD | 3 | | 9 | | 3 | | 13 | | 3 | | 7 | | 2 | | 6
| OA | 6 | | 8 | | 4 | | 11 | | 5 | | 6 | | 3 | | 5
| TC >240mg/dl | 21 | | 22 | | 16 | | 31 | | 20 | | 16 | | 10 | | 14
| BP>140/90 mmHg | 60 | | 41 | | 45 | | 56 | | 57 | | 30 | | 28 | | 26
| | 0.30 | 0.10 | 0.30 | 0.10 | 0.30 | 0.10 | 0.30 | 0.10 | 0.30 | 0.10 | 0.30 | 0.10 | 0.30 | 0.10 | 0.30 | 0.10
Prevented excess cases of disease. (Treatment efficacy of 0.30 and 0.10.) | DMII | 6 | 2 | 3 | 1 | 4 | 1 | 4 | 1 | 5 | 2 | 2 | 1 | 3 | 1 | 2 | 1
| GBD | 2 | 1 | 5 | 2 | 2 | 1 | 6 | 2 | 2 | 1 | 3 | 1 | 1 | 0 | 3 | 1
| CHD | 1 | 0 | 3 | 1 | 1 | 0 | 4 | 1 | 1 | 0 | 2 | 1 | 0 | 0 | 2 | 1
| OA | 2 | 1 | 2 | 1 | 1 | 0 | 3 | 1 | 2 | 1 | 2 | 1 | 1 | 0 | 2 | 1
| total diseases | 11 | 4 | 13 | 5 | 8 | 2 | 17 | 5 | 10 | 4 | 9 | 4 | 5 | 1 | 9 | 4
| TC >240mg/dl | 6 | 2 | 7 | 2 | 5 | 2 | 9 | 3 | 6 | 2 | 5 | 2 | 3 | 1 | 4 | 1
| BP>140/90 mmHg | 18 | 6 | 12 | 4 | 14 | 5 | 17 | 6 | 17 | 6 | 9 | 3 | 8 | 3 | 8 | 3
| total risk factors | 24 | 8 | 19 | 6 | 19 | 7 | 26 | 9 | 23 | 8 | 14 | 5 | 11 | 4 | 12 | 4
Total burden of adult disease per 1000 ^3^ | DMII | 54 | | 69 | | 50 | | 74 | | 44 | | 57 | | 51 | | 57
| GBD | 29 | | 123 | | 34 | | 127 | | 30 | | 108 | | 34 | | 105
| CHD | 106 | | 97 | | 104 | | 95 | | 100 | | 93 | | 104 | | 91
| OA | 41 | | 85 | | 39 | | 88 | | 37 | | 91 | | 40 | | 76
| total diseases | 230 | | 374 | | 227 | | 384 | | 211 | | 349 | | 229 | | 329
| TC >240mg/dl | 333 | | 375 | | 319 | | 372 | | 316 | | 350 | | 327 | | 344
| BP>140/90 mmHg | 352 | | 386 | | 339 | | 394 | | 317 | | 348 | | 342 | | 340
| total risk factors | 685 | | 761 | | 658 | | 766 | | 633 | | 698 | | 669 | | 684
| | 0.30 | 0.10 | 0.30 | 0.10 | 0.30 | 0.10 | 0.30 | 0.10 | 0.30 | 0.10 | 0.30 | 0.10 | 0.30 | 0.10 | 0.30 | 0.10
Proportion prevented | diseases | 0.05 | 0.02 | 0.03 | 0.01 | 0.04 | 0.01 | 0.04 | 0.01 | 0.05 | 0.02 | 0.03 | 0.01 | 0.02 | 0.00 | 0.03 | 0.01
| risk factors | 0.04 | 0.01 | 0.02 | 0.01 | 0.03 | 0.01 | 0.03 | 0.01 | 0.04 | 0.01 | 0.02 | 0.01 | 0.02 | 0.01 | 0.02 | 0.01
NNS | diseases | 91 | 250 | 77 | 200 | 125 | 500 | 59 | 200 | 100 | 250 | 111 | 250 | 200 | 1000 | 111 | 250
| risk factors | 42 | 125 | 53 | 167 | 53 | 143 | 38 | 111 | 43 | 125 | 71 | 200 | 91 | 250 | 83 | 250
NNT | diseases | 25 | 69 | 15 | 39 | 26 | 104 | 16 | 53 | 26 | 65 | 16 | 36 | 26 | 128 | 14 | 31
| risk factors | 11 | 34 | 10 | 32 | 11 | 30 | 10 | 30 | 11 | 32 | 10 | 29 | 12 | 32 | 10 | 31

## References for Appendix Q

1 Ogden CL, Flegal KM, Carroll MD, Johnson CL. Prevalence and trends in overweight among US children and adolescents, 1999-2000. JAMA. 2002;288(14Oct 9):1728-1732. [pmid: 12365956].
2 Zephier E, Himes JH, Story M. Prevalence of overweight and obesity in American Indian School children and adolescents in the Aberdeen area: a population study. Int J Obes Relat Metab Disord. 1999;23(Suppl 2):S28-30. S28–S30. [pmid: 10340802].
3 Must A, Spadano J, Coakley EH, Field AE, Colditz G, Dietz WH. The disease burden associated with overweight and obesity. JAMA. 1999;282(16):1523-1529. [pmid: 10546691].
4 Freedman DS, Khan LK, Dietz WH, Srinivasan SR, Berenson GS. Relationship of childhood obesity to coronary heart disease risk factors in adulthood: the Bogalusa Heart Study. Pediatrics. 2001;108(3):712-718. [pmid: 11533341].
5 Guo SS, Wu W, Chumlea WC, Roche AF. Predicting overweight and obesity in adulthood from body mass index values in childhood and adolescence. American Journal of Clinical Nutrition. 2002;76(3):653-658. [pmid: 12198014].